# REFERENCES

1 Chang C-K, Hayes R, Broadbent M, et al. All-cause mortality among people with serious mental illness (SMI), substance use disorders, and depressive disorders in southeast London: a cohort study. BMC Psychiatry. 2010;10(1):77. [pmid: 20920287].
2 Brown AS, Birthwhistle J. Excess mortality of mental illness. Br J Psychiatry. 1996;169(3):383-4. [pmid: 8879735].
3 Parks J, Svendsen D, Singer P, et al. Morbidity and Mortality in People with Serious Mental Illness (Technical Report 13). Alexandria, VA. National Association of State Mental Health Progaram Directors. 2006.
4 Colton CW, Manderscheid RW. Congruencies in increased mortality rates, years of potential life lost, and causes of death among public mental health clients in eight states. Prev Chronic Dis. 2006;3(2):A42. [pmid: 16539783].
5 Hennekens CH. Increasing global burden of cardiovascular disease in general populations and patients with schizophrenia. J Clin Psychiatry. 2007;68(Suppl 4):4-7. [pmid: 17539693].
6 Kilbourne AM, Morden NE, Austin K, et al. Excess heart-disease-related mortality in a national study of patients with mental disorders: identifying modifiable risk factors. Gen Hosp Psychiatry. 2009;31(6):555-63. [pmid: 19892214].
7 Wu EQ, Birnbaum HG, Shi L, et al. The economic burden of schizophrenia in the United States in 2002. J Clin Psychiatry. 2005;66(9):1122-9. [pmid: 16187769].
8 Peele PB, Xu Y, Kupfer DJ. Insurance expenditures on bipolar disorder: clinical and parity implications. Am J Psychiatry. 2003;160(7):1286-90. [pmid: 12832243].
9 Merikangas KR, Akiskal HS, Angst J, et al. Lifetime and 12-month prevalence of bipolar spectrum disorder in the National Comorbidity Survey replication. Arch Gen Psychiatry. 2007;64(5):543-52. [pmid: 17485606].
10 Simon GE, Unutzer J. Health care utilization and costs among patients treated for bipolar disorder in an insured population. Psychiatr Serv. 1999;50(10):1303-8. [pmid: 10506298].
11 Bryant-Comstock L, Stender M, Devercelli G. Health care utilization and costs among privately insured patients with bipolar I disorder. Bipolar Disord. 2002;4(6):398-405. [pmid: 12519100].
12 Rosenberg SD, Swanson JW, Wolford GL, et al. The five-site health and risk study of blood-borne infections among persons with severe mental illness. Psychiatr Serv. 2003;54(6):827-35. [pmid: 12773596].
13 Hsu JH, Chien IC, Lin CH, et al. Incidence of diabetes in patients with schizophrenia: a population-based study. Can J Psychiatry. 2011;56(1):19-26. [pmid: 21324239].
14 Dixon L, Weiden P, Delahanty J, et al. Prevalence and correlates of diabetes in national schizophrenia samples. Schizophr Bull. 2000;26(4):903-12. [pmid: 11087022].
15 van Winkel R, De Hert M, Van Eyck D, et al. Prevalence of diabetes and the metabolic syndrome in a sample of patients with bipolar disorder. Bipolar Disord. 2008;10(2):342-8. [pmid: 18271914].
16 Sokal J, Messias E, Dickerson FB, et al. Comorbidity of medical illnesses among adults with serious mental illness who are receiving community psychiatric services. J Nerv Ment Dis. 2004;192(6):421-7. [pmid: 15167405].
17 Bresee LC, Majumdar SR, Patten SB, et al. Prevalence of cardiovascular risk factors and disease in people with schizophrenia: a population-based study. Schizophr Res. 2010;117(1):75-82. [pmid: 20080392].
18 Weiner M, Warren L, Fiedorowicz JG. Cardiovascular morbidity and mortality in bipolar disorder. Ann Clin Psychiatry. 2011;23(1):40-7. [pmid: 21318195].
19 McCreadie RG. Diet, smoking and cardiovascular risk in people with schizophrenia: descriptive study. Br J Psychiatry. 2003;183:534-9. [pmid: 14645025].
20 McElroy SL. Obesity in patients with severe mental illness: overview and management. J Clin Psychiatry. 2009;70(Suppl 3):12-21. [pmid: 19570497].
21 Fountoulakis KN, Siamouli M, Panagiotidis P, et al. Obesity and smoking in patients with schizophrenia and normal controls: a case-control study. Psychiatry Res. 2010;176(1):13-6. [pmid: 20079934].
22 Swartz MS, Wagner HR, Swanson JW, et al. Substance Use and Psychosocial Functioning in Schizophrenia Among New Enrollees in the NIMH CATIE Study. Psychiatr Serv. 2006;57(8):1110-1116. [pmid: 16870961].
23 Brown S, Birtwistle J, Roe L, et al. The unhealthy lifestyle of people with schizophrenia. Psychol Med. 1999;29(3):697-701. [pmid: 10405091].
24 Cohen CI. Poverty and the course of schizophrenia: implications for research and policy. Hosp Community Psychiatry. 1993;44(10):951-8. [pmid: 8225275].
25 Fischer PJ, Breakey WR. The epidemiology of alcohol, drug, and mental disorders among homeless persons. Am Psychol. 1991;46(11):1115-28. [pmid: 1772149].
26 Trauer T, Duckmanton RA, Chiu E. A study of the quality of life of the severely mentally ill. Int J Soc Psychiatry. 1998;44(2):79-91. [pmid: 9675628].
27 Desai MM, Rosenheck RA, Druss BG, et al. Receipt of nutrition and exercise counseling among medical outpatients with psychiatric and substance use disorders. J Gen Intern Med. 2002;17(7):556-60. [pmid: 12133146].
28 Druss BG, Rosenheck RA, Desai MM, et al. Quality of preventive medical care for patients with mental disorders. Med Care. 2002;40(2):129-36. [pmid: 11802085].
29 Green JL, Gazmararian JA, Rask KJ, et al. Quality of diabetes care for under-served patients with and without mental illness: site of care matters. Psychiatr Serv. 2010;61(12):1204-10. [pmid: 21123404].
30 Frayne SM, Halanych JH, Miller DR, et al. Disparities in diabetes care: impact of mental illness. Arch Intern Med. 2005;165(22):2631-8. [pmid: 16344421].
31 Mitchell AJ, Lord O. Do deficits in cardiac care influence high mortality rates in schizophrenia? A systematic review and pooled analysis. J Psychopharmacol. 2010;24(4 Suppl):69-80. [pmid: 20923922].
32 Druss BG, Bradford DW, Rosenheck RA, et al. Mental disorders and use of cardiovascular procedures after myocardial infarction. JAMA. 2000;283(4):506-11. [pmid: 10659877].
33 Ray WA, Chung CP, Murray KT, et al. Atypical antipsychotic drugs and the risk of sudden cardiac death. N Engl J Med. 2009;360(3):225-35. [pmid: 19144938].
34 Bergman RN, Ader M. Atypical antipsychotics and glucose homeostasis. J Clin Psychiatry. 2005;66(4):504-14. [pmid: 15816794].
35 Koro CE, Meyer JM. Atypical antipsychotic therapy and hyperlipidemia: a review. Essent Psychopharmacol. 2005;6(3):148-57. [pmid: 15869022].
36 Wirshing DA. Schizophrenia and obesity: impact of antipsychotic medications. J Clin Psychiatry. 2004;65(Suppl 18):13-26. [pmid: 15600381].
37 American Board of Internal Medicine. Combined Training Internal Medicine. Available at: www.abim.org/certification/policies/combinedim/compsych.aspx. Accessed June 28, 2011.
38 Druss BG. Improving medical care for persons with serious mental illness: challenges and solutions. J Clin Psychiatry. 2007;68(Suppl 4):40-4. [pmid: 17539699].
39 Bradford DW, Kim MM, Braxton LE, et al. Access to medical care among persons with psychotic and major affective disorders. Psychiatr Serv. 2008;59(8):847-52. [pmid: 18678680].
40 Rollman BL, Belnap BH, Mazumdar S, et al. A randomized trial to improve the quality of treatment for panic and generalized anxiety disorders in primary care. Arch Gen Psychiatry. 2005;62(12):1332-41. [pmid: 16330721].
41 Roy-Byrne P, Craske MG, Sullivan G, et al. Delivery of evidence-based treatment for multiple anxiety disorders in primary care: a randomized controlled trial. JAMA. 2010;303(19):1921-8. [pmid: 20483968].
42 Butler M, Kane RL, McAlpine D, et al. Integration of mental health/substance abuse and primary care. Evid Rep Technol Assess (Full Rep). 2008;(173):1-362. [pmid: 19408966].
43 Rubenstein LV, Williams JW Jr, Danz M, et al. Determining Key Features of Effective Depression Interventions. Available at: http://www.ncbi.nlm.nih.gov/books/NBK48533/. Accessed June 28, 2011. 2009.
44 Grumbach K, Bodenheimer T. A primary care home for Americans: putting the house in order. JAMA. 2002;288(7):889-93. [pmid: 12186609].
45 Stange KC, Nutting PA, Miller WL, et al. Defining and measuring the patient-centered medical home. J Gen Intern Med. 2010;25(6):601-12. [pmid: 20467909].
46 Gelberg L, Andersen RM, Leake BD. The Behavioral Model for Vulnerable Populations: application to medical care use and outcomes for homeless people. Health Serv Res. 2000;34(6):1273-302. [pmid: 10654830].
47 Wilczynski NL, Haynes RB, Lavis JN, et al. Optimal search strategies for detecting health services research studies in MEDLINE. CMAJ. 2004;171(10):1179-85. [pmid: 15534310].
48 Haynes RB, McKibbon KA, Wilczynski NL, et al. Optimal search strategies for retrieving scientifically strong studies of treatment from Medline: analytical survey. BMJ. 2005;330(7501):1179. [pmid: 15894554].
49 Cochrane Collaboration. Cochrane Handbook for Systematic Reviews of Interventions. Chapter 6: Searching for studies. Section 6. 1. March. 2011;4:11.
50 Cochrane Effective Practice and Organisation of Care Group. EPOC resources for review authors. Available at: http://epoc.cochrane.org/epoc-resources-review-authors. Accessed June 28, 2011.
51 Bodenheimer T, Wagner EH, Grumbach K. Improving primary care for patients with chronic illness: the chronic care model, Part 2. JAMA. 2002;288(15):1909-14. [pmid: 12377092].
52 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. Accessed June 28, 2011.
53 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-6. [pmid: 18436948].
54 Druss BG, von Esenwein SA, Compton MT, et al. A randomized trial of medical care management for community mental health settings: the Primary Care Access, Referral, and Evaluation (PCARE) study. Am J Psychiatry. 2010;167(2):151-9. [pmid: 20008945].
55 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: part I. Intervention and implementation in a randomized effectiveness trial. Psychiatr Serv. 2006;57(7):927-36. [pmid: 16816276].
56 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatr Serv. 2006;57(7):937-45. [pmid: 16816277].
57 Kilbourne AM, Post EP, Nossek A, et al. Improving medical and psychiatric outcomes among individuals with bipolar disorder: a randomized controlled trial. Psychiatr Serv. 2008;59(7):760-8. [pmid: 18586993].
58 Kilbourne AM, Biswas K, Pirraglia PA, et al. Is the collaborative chronic care model effective for patients with bipolar disorder and co-occurring conditions?. J Affect Disord. 2009;112(1–3):256-61. [pmid: 18504059].
59 Kilbourne AM, Post EP, Nossek A, et al. Service delivery in older patients with bipolar disorder: a review and development of a medical care model. Bipolar Disord. 2008;10(6):672-83. [pmid: 18837861].
60 Druss BG, Rohrbaugh RM, Levinson CM, et al. Integrated medical care for patients with serious psychiatric illness: a randomized trial. Arch Gen Psychiatry. 2001;58(9):861-8. [pmid: 11545670].
61 Health care reform for Americans with severe mental illnesses: report of the National Advisory Mental Health Council. Am J Psychiatry. 1993;150(10):1447-65. [pmid: 8379547].
62 Wagner EH. The role of patient care teams in chronic disease management. BMJ. 2000;320(7234):569-72. [pmid: 10688568].
63 Von Korff M, Gruman J, Schaefer J, et al. Collaborative management of chronic illness. Ann Intern Med. 1997;127(12):1097-102. [pmid: 9412313].
64 Bodenheimer T, Wagner EH, Grumbach K. Improving primary care for patients with chronic illness. JAMA. 2002;288(14):1775-9. [pmid: 12365965].
65 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. 1992;30(6):473-83. [pmid: 1593914].
66 McHorney CA, Ware JE Jr, Raczek AE. The MOS 36-Item Short-Form Health Survey (SF-36): II. Psychometric and clinical tests of validity in measuring physical and mental health constructs. Med Care. 1993;31(3):247-63. [pmid: 8450681].
67 McHorney CA, Ware JE Jr, Lu JF, et al. The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med Care. 1994;32(1):40-66. [pmid: 8277801].
68 Ware J Jr, Kosinski M, Keller SD. A 12-Item Short-Form Health Survey: construction of scales and preliminary tests of reliability and validity. Med Care. 1996;34(3):220-33. [pmid: 8628042].
69 Kilbourne AM, Pirraglia PA, Zongshan L, et al. Quality of General Medical Care Among Patients With Serious Mental Illness: Does Colocation of Services Matter?. Psychiatr Serv. 2011. In press.
70 Pirraglia PA, Kilbourne AM, Lai Z, et al. Colocated general medical care and preventable hospital admissions for veterans with serious mental illness. Psychiatr Serv. 2011;62(5):554-7. [pmid: 21532086].
71 Rosenheck RA, Neale MS. Cost-effectiveness of intensive psychiatric community care for high users of inpatient services. Arch Gen Psychiatry. 1998;55(5):459-66. [pmid: 9596049].
72 The Management of Bipolar Disorder Working Group. VA/DoD clinical practice guideline for management of bipolar disorder in adults. Washington, (DC). Department of Veterans Affairs, Department of Defense. 2010. Available at: http://www.guideline.gov/content.aspx?id=16314. Accessed August 30, 2011.
73 Yatham LN, Kennedy SH, O’Donovan C, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) guidelines for the management of patients with bipolar disorder: update 2007. Bipolar Disord. 2006;8(6):721-39. [pmid: 17156158].
74 Druss BG, Zhao L, von Esenwein SA, et al. The Health and Recovery Peer (HARP) Program: A peer-led intervention to improve medical self-management for persons with serious mental illness. Schizophr Res. 2010.
75 Li Y, Cai X, Du H, et al. Mentally ill medicare patients less likely than others to receive certain types of surgery. Health Aff (Millwood). 2011;30(7):1307-15. [pmid: 21734205].