# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the Department of Veterans Affairs’ Evidence-based Synthesis Program. The topic was selected after a formal topic nomination and prioritization process that included representatives from the Office of Mental Health Services, Health Services Research and Development, the Mental Health Quality Enhancement Research Initiative (QUERI), and the Office of Mental Health and Primary Care Integration.

The final key questions (KQs) were:

KQ 1 What types of care models have been evaluated prospectively that integrate mental health care and primary medical care with the goal of improving general medical outcomes for individuals with serious mental illness (SMI)?
KQ 2 Do models of integrated care for individuals with SMI improve the process of care for preventive services (e.g., colorectal cancer screening) and chronic disease management (e.g., annual eye examination in patients with diabetes mellitus [DM])?
KQ 3 (3a) Do models of integrated care for individuals with SMI improve general functional status outcomes (e.g., as measured by SF-36) or disease-specific functional status outcomes (e.g., Seattle Angina Questionnaire) related to medical care for chronic medical conditions such as DM, hypertension, or heart failure? (3b) Do models of integrated care for individuals with SMI improve clinical outcomes related to preventive services (e.g., influenza rates) and chronic medical care (e.g., kidney disease, amputations, retinopathy in patients with coexisting DM)?
KQ 4 What are the gaps in evidence for determining how best to integrate care to improve general medical outcomes for individuals with SMI?

## ANALYTIC FRAMEWORK

We developed and followed a standard protocol for all steps of this review. Our approach was guided by an analytic framework adapted from a previously developed behavioral model for vulnerable populations.46 Figure 1 shows the analytic framework.

Figure 1 Analytic framework for general medical outcomes for SMI

## SEARCH STRATEGY

We searched for English-language publications in MEDLINE^®^ (via PubMed^®^), Embase^®^, PsycINFO^®^, and the Cochrane Library from database inception through March 10, 2011. Search terms included terms for schizophrenia and bipolar disorder; a broad set of terms for care models; and a set of terms for randomized controlled trials (RCTs) or quasi-experimental studies adapted from the Cochrane Effective Practice and Organization of Care Search.47–50 The search strategies were developed in consultation with a master librarian. The search terms and MeSH headings for the search strategies appear in Appendix A. We supplemented electronic searching by examining the bibliographies of the included studies and other review articles. Finally, we searched ClinicalTrials.gov using the terms “serious mental illness” or “SMI” to assess for evidence of publication bias (completed but unpublished studies) and ongoing studies that may fill gaps in evidence.

## STUDY SELECTION

Using prespecified inclusion/exclusion criteria (Appendix B), two reviewers assessed the lists of titles and abstracts from the databases for further review. Full-text articles of potentially relevant abstracts were retrieved for further review. To be included in our evidence report, a study had to (1) be a randomized controlled trial (RCT) or quasi-experimental study design, (2) evaluate a care model designed to integrate mental and general medical care, (3) include a sample of adult patients with SMI (i.e., schizophrenia, bipolar disorder, schizoaffective disorder) or who met the definition of SMI based on low functional status (e.g., by Global Assessment of Functioning score) and (4) report a relevant outcome. If both preliminary and final reports were published, the final data analysis was utilized. The eligibility criteria are described in detail in Table 1.

Table 1 Summary of inclusion and exclusion criteria

Study characteristic | Inclusion criteria | Exclusion criteria
Study design | RCT or quasi-experimental study defined as nonrandomized cluster controlled trial, controlled before-and-after study, or interrupted time series | Non-English language publication Cross-sectional and other observational designs not listed as included
Population | Adults ≥ 18 years of age with schizophrenia, schizoaffective disorder, or bipolar disorder A sample described as persons having SMI (based on low functional status and chronicity) and at least 25% are diagnosed with schizophrenia, schizoaffective disorder, or bipolar disorder | Primary substance abuse
Interventions | Interventions with a stated goal to improve general medical care or outcomes through an integrated model and either one of the following:; 1. a system redesign that adds care provider(s) to directly address or coordinate mental and general medical care; 2. interventions that do not add providers but include at least 3 of the following elements:; - decision support; - information systems; - self-management support; - team care; - enhanced communications between mental health providers and general medical providers | Interventions designed to be implemented primarily in the community (nonmedical settings) Interventions designed to affect only one specific outcome or aspect of general medical health (e.g., weight loss or smoking cessation, etc.)
Comparators | Usual care or other quality improvement strategy | None
Outcomes | Process of care measures for preventive services (e.g., influenza vaccination rate), or chronic disease management (e.g., lipid screening or glucose control in a patient with diabetes mellitus) Clinical outcomes (e.g., rate of influenza infection) Physical functioning (SF-36 Physical Component) or disease-specific symptoms (e.g., Seattle Angina Questionnaire) measured by a validated instrument | Only measures of mental health care processes, symptom status, or functional status
Setting | Outpatient mental health | Hospital-based (inpatient) settings Community-based settings (e.g., senior centers, homeless shelters)

## DATA ABSTRACTION

A trained researcher abstracted data from published articles and reports into a data abstraction form; a second reviewer overread the abstracted data. We resolved disagreements by consensus among the first and second reviewer or by obtaining a third reviewer’s opinion when consensus could not be reached. We abstracted the following data for each included study:

- study design
- setting
- population characteristics
- subject eligibility and exclusion criteria
- number of subjects and providers
- intervention(s)
- comparison(s)
- length of followup
- outcome(s)

Intervention characteristics were categorized using the chronic care model and selected elements of the patient centered medical home. The chronic care model classifies health care elements into six domains: health system, delivery system design, decision support, clinical information systems, self-management support, and the community.51 With the exception of health system factors (e.g., quality-based incentives), we used these domains along with the following PCMH elements: a primary treating clinician, team-based care, and methods to enhance access to care.

We grouped immunizations and cancer screening into the general category of preventive services outcomes. For chronic disease care processes, we prioritized those with an established link to clinical outcomes (e.g., blood pressure control in patients with diabetes mellitus). Some care processes (e.g., cholesterol measurement) could be classified as preventive screening or chronic disease management. When these outcomes were reported separately, we grouped them according to our analytic framework, but in some cases we could not follow this approach because preventive and chronic disease outcomes were reported only in aggregate form.

## QUALITY ASSESSMENT

We assessed the risk of bias pertaining to KQs 2 and 3 using the key quality criteria described in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews,52 adapted for this specific topic (Appendix C). For RCTs, we abstracted data on adequacy of randomization and allocation concealment, comparability of groups at baseline, blinding, completeness of followup and differential loss to followup, whether incomplete data were addressed appropriately, validity of outcome measures and completeness of outcomes reporting, and conflict of interest. Using these data elements, we assigned a summary quality score of Good, Fair, or Poor to individual RCTs. We assessed studies for applicability to U.S. Veterans.

## DATA SYNTHESIS

We constructed summary tables showing the study characteristics and results for all included studies, organized by KQ, intervention, or clinical condition, as appropriate. We critically analyzed studies to compare their characteristics, methods, and findings. We compiled a summary of findings for each KQ or clinical topic and drew conclusions based on qualitative synthesis of the findings. There were not sufficient studies to perform quantitative synthesis (meta-analysis).

## RATING THE BODY OF EVIDENCE

We assessed the overall quality of evidence for outcomes using a method developed by the Grades of Recommendation, Assessment, Development, and Evaluation (GRADE) Working Group,53 which classified the grade of evidence across outcomes according to the following criteria:

- High—Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate—Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low—Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

## PEER REVIEW

A draft version of this report was reviewed by technical experts as well as clinical leadership, and their comments are provided in Appendix D.