# GLOSSARY

Abstract screening: The stage in a systematic review during which titles and abstracts of articles identified in the literature search are screened for inclusion or exclusion based on established criteria. Articles that pass the abstract screening stage are promoted to the full-text review stage.
ClinicalTrials.gov: A registry and results database of federally and privately supported clinical trials conducted in the United States and around the world. ClinicalTrials.gov provides information about a trial’s purpose, location, participant characteristics, among other details.
Cochrane Database of Systematic Reviews: A bibliographic database of peer-reviewed systematic reviews and protocols prepared by the Cochrane Review Groups in The Cochrane Collaboration.
Companion article: A companion article is a publication from a trial that is not the paper containing the main results of that trial. It may be a methods paper, a report of subgroup analyses, a report of combined analyses, or other auxiliary topic that adds information to the interpretation of the main paper.
Confidence interval (CI): The range in which a particular result (such as a laboratory test) is likely to occur for everyone who has a disease. “Likely” usually means 95 percent of the time. Clinical research studies are conducted on only a certain number of people with a disease rather than all the people who have the disease. The study’s results are true for the people who were in the study but not necessarily for everyone who has the disease. The confidence interval is a statistical estimate of how much the study findings would vary if other different people participated in the study. A confidence interval is defined by two numbers, one lower than the result found in the study and the other higher than the study’s result. The size of the confidence interval is the difference between these two numbers.
Data abstraction: The stage of a systematic review that involves a pair of trained researchers extracting reported findings specific to the research questions from the full-text articles that met the established inclusion criteria. These data form the basis of the evidence synthesis.
Exclusion criteria: The criteria, or standards, set out before a study or review. Exclusion criteria are used to determine whether a person should participate in a research study or whether an individual study should be excluded in a systematic review. Exclusion criteria may include age, previous treatments, and other medical conditions.
Full-text review: The stage of a systematic review in which a pair of trained researches evaluates the full-text of study articles for potential inclusion in the review.
GRADE: Grading of Recommendations Assessment, Development and Evaluation (GRADE), a system of assessing the quality of medical evidence and evaluating the strength of recommendations based on the evidence.
Inclusion criteria: The criteria, or standards, set out before the systematic review. Inclusion criteria are used to determine whether an individual study can be included in a systematic review. Inclusion criteria may include population, study design, gender, age, type of disease being treated, previous treatments, and other medical conditions.
Nonrandomized study: Any quantitative study estimating the effectiveness of an intervention (harm or benefit) that does not use randomization to allocate units to comparison groups (including studies where “allocation” occurs in the course of usual treatment decisions or peoples’ choices; i.e., studies usually called “observational”). There are many possible types of nonrandomized intervention studies, including cohort studies, case-control studies, controlled before-and-after studies, interrupted-time-series studies, and controlled trials that do not use appropriate randomization strategies (sometimes called quasi-randomised studies).
Observational study: A study in which the investigators do not seek to intervene but simply observe the course of events. Changes or differences in one characteristic (e.g., whether or not people received the intervention of interest) are studied in relation to changes or differences in other characteristics (e.g., whether or not they died), without action by the investigator. Observational studies provide weaker empirical evidence than do experimental studies because of the potential for large confounding biases to be present when there is an unknown association between a factor and an outcome.
PsycINFO^®^: An abstracting and indexing database of peer-reviewed literature in the behavioral sciences and mental health.
Publication bias: The tendency of researchers to publish experimental findings that have a positive result, while not publishing the findings when the results are negative or inconclusive. The effect of publication bias is that published studies may be misleading. When information that differs from that of the published study is not known, people are able to draw conclusions using only information from the published studies.
PubMed^®^: A database of citations for biomedical literature from MEDLINE^®^, life science journals, and online books in the fields of medicine, nursing, dentistry, veterinary medicine, the health care system, and preclinical sciences.
Quasi-experimental study: Often described as a nonrandomized, pre-post intervention study. A study based on a true experimental design meets two criteria: manipulation of a variable factor between two or more groups and random assignment of participants to those groups. A quasi-experimental study uses the first criterion, but participants are not randomly assigned to groups. This means a researcher cannot draw conclusions about cause and effect. Quasi-experimental study designs are frequently used when it is not logistically feasible or ethical to conduct a randomized controlled trial.
Randomized controlled trial: A prospective, analytical, experimental study using primary data generated in the clinical environment. Individuals similar at the beginning of the trial are randomly allocated to two or more treatment groups and the outcomes the groups are compared after sufficient followup time. Properly executed, the RCT is the strongest evidence of the clinical efficacy of preventive and therapeutic procedures in the clinical setting.
Risk: A way of expressing the chance that something will happen. It is a measure of the association between exposure to something and what happens (the outcome). Risk is the same as probability, but it usually is used to describe the probability of an adverse event. It is the rate of events (such as breast cancer) in the total population of people who could have the event (such as women of a certain age).
Serious mental illness (SMI): Defined in this report according to the definition stipulated in Public Law (P.L.) 102–321; that is, a diagnosable mental, behavioral, or emotional disorder, at some time during the past year, that met the criteria in the Diagnostic and Statistical Manual of Mental Disorders, 4^th^edition (DSM-IV) (American Psychiatric Association, 1994) and resulted in functional impairment that substantially interfered with or limited one or more major life activities.
Statistical significance: A mathematical technique to measure whether the results of a study are likely to be true. Statistical significance is calculated as the probability that an effect observed in a research study is occurring because of chance. Statistical significance is usually expressed as a P-value. The smaller the P-value, the less likely it is that the results are due to chance (and more likely that the results are true). Researchers generally believe the results are probably true if the statistical significance is a P-value less than 0.05 (p<.05).
Strength of evidence (SOE): A measure of how confident reviewers are about decisions that may be made based on a body of evidence. SOE is evaluated using one of four grades: (1) High confidence that the evidence reflects the true effect; further research is very unlikely to change reviewer confidence in the estimate of effect; (2) moderate confidence that the evidence reflects the true effect; further research may change the confidence in the estimate of effect and may change the estimate; (3) low confidence that the evidence reflects the true effect; further research is likely to change the confidence in the estimate of effect and is likely to change the estimate; and (4) insufficient; the evidence either is unavailable or does not permit a conclusion.
Systematic review: A summary of the clinical literature. A systematic review is a critical assessment and evaluation of all research studies that address a particular clinical issue. The researchers use an organized method of locating, assembling, and evaluating a body of literature on a particular topic using a set of specific criteria. A systematic review typically includes a description of the findings of the collection of research studies. The systematic review may also include a quantitative pooling of data, called a meta-analysis.
Time-series study: A quasi-experimental research design in which periodic measurements are made on a defined group of individuals both before and after implementation of an intervention. Time series studies are often conducted for the purpose of determining the intervention or treatment effect.