# EXCLUDED STUDIES

All studies listed below were reviewed in their full-text version and excluded for the reason indicated. An alphabetical reference list follows the table.

Reference | Not SMI | Not outpatient | Not RCT | Not integrated care | No medical outcomes | Not peer-reviewed | Not Westernized culture
Adair et al., 2005 (1039) | | | X
Baker et al., 2009 (1055) | | | X
Bauer et al., 2001 (1592) | | | | X
Bauer et al., 2007 (1558) | | | | | | X
Byng et al., 2004 (434) | | | | | X
Chafetz et al., 2008 (152) | | X
Chiverton et al., 2007 (185) | X
Ciompi et al., 1992 (907) | | | X
Davies et al., 2008 (1134) | | | X
Desai et al., 2002 (16) | X
Desai et al., 2002 (23) | X
Dewa et al., 2009 (82) | X
Dickerson et al., 2003 (11) | | | X
Donald et al., 2005 (395) | | | X
Drew et al., 2007 (217) | | | X
Druss et al., 2010 (21) | | | | X
Essock et al., 1998 (687) | | | | | X
Essock et al., 1995 (820) | | | | | X
Essock et al., 2006 (319) | | | | X
Forsberg et al., 2008 (1553) | | | | X
Harvey et al., 2005 (1200) | | | | X
Jerrell et al., 1995 (806) | | | | | X
Kahn et al., 2009 (46) | X
Kalichman et al., 1995 (832) | | | | X
Katon et al., 1991 (929) | X
Kemp et al., 2010 (1234) | | | | X
Know et al., 2006 (1267) | | | | | | | X
Madhusoodanam et al., 2006 (1298) | | | X
Malla et al., 1998 (675) | | | | X
McKibbin et al., 2010 (1324) | | | | X
Ohlsen et al., 2005 (341) | | | X
O’Kearney et al., 2004 (1362) | | | X
Pirraglia et al., 2009 (1380) | | | X
Poulin et al., 2007 (1383) | | | | X
Ridgely et al., 1996 (774) | | | X
Rivera et al., 2007 (225) | | | | X
Robson et al., 1984 (960) | X
Rubin et al., 2005 (376) | | X
Ryan et al., 2007 (207) | X
Sartorius et al., 1993 (887) | X
Sata et al., 1999 (614) | X
Schmidt-Kraepelin et al., 2009 (55) | | | | | X
Sim et al., 2006 (1446) | | | | X
Simon et al., 2006 (1694) | | | | X
Snyder et al., 2008 (1693) | | | | X
Symonds et al., 2007 (1692) | X
Taborda et al., 2003 (471) | | | | | | X
Thompson et al., 2006 (1484) | | | | X
Welch et al., 2009 (84) | | | X
Wright et al., 2006 (308) | | | X

## LIST OF EXCLUDED STUDIES

Adair CE, McDougall GM, Mitton CR, et al. Continuity of Care and Health Outcomes Among Persons With Severe Mental Illness. Psychiatr Serv. 2005;56(9):1061-1069. [pmid: 16148318].
Baker A, Richmond R, Castle D, et al. Coronary heart disease risk reduction intervention among overweight smokers with a psychotic disorder: Pilot trial. Aust N Z J Psychiatry. 2009;43(2):129-135. [pmid: 19153920].
Bauer MS. The collaborative practice model for bipolar disorder: design and implementation in a multi-site randomized controlled trial. Bipolar Disorders. 2001:233-44. [pmid: 11903206].
Bauer Ms KAM. Outcome and Costs in a Randomized Controlled Effectiveness Trial of a Collaborative Chronic Care Model for Bipolar Disorder. Journal of Mental Health Policy and Economics. 2007:S3.
Byng R, Jones R, Leese M, et al. Exploratory cluster randomised controlled trial of shared care development for long-term mental illness. Br J Gen Pract. 2004;54(501):259-66. [pmid: 15113492].
Chafetz L, White M, Collins-Bride G, et al. Clinical trial of wellness training: health promotion for severely mentally ill adults. J Nerv Ment Dis. 2008;196(6):475-83. [pmid: 18552625].
Chiverton P, Lindley P, Tortoretti DM, et al. Well balanced: 8 steps to wellness for adults with mental illness and diabetes. J Psychosoc Nurs Ment Health Serv. 2007;45(11):46-55. [pmid: 18041357].
Ciompi L, Dauwalder HP, Maier C, et al. The pilot project ‘Soteria Berne’. Clinical experiences and results. Br J Psychiatry Suppl. 1992;(18):145-53. [pmid: 1356365].
Davies LM, Barnes TRE, Jones PB, et al. A randomized controlled trial of the cost-utility of second-generation antipsychotics in people with psychosis and eligible for clozapine. Value in Health. 2008;11(4):549-562. [pmid: 18179662].
Desai MM, Rosenheck RA, Druss BG, et al. Mental disorders and quality of care among postacute myocardial infarction outpatients. J Nerv Ment Dis. 2002;190(1):51-3. [pmid: 11838034].
Desai MM, Rosenheck RA, Druss BG, et al. Receipt of nutrition and exercise counseling among medical outpatients with psychiatric and substance use disorders. J Gen Intern Med. 2002;17(7):556-60. [pmid: 12133146].
Dewa CS, Hoch JS, Carmen G, et al. Cost, effectiveness, and cost-effectiveness of a collaborative mental health care program for people receiving short-term disability benefits for psychiatric disorders. Can J Psychiatry. 2009;54(6):379-88. [pmid: 19527558].
Dickerson FB, McNary SW, Brown CH, et al. Somatic healthcare utilization among adults with serious mental illness who are receiving community psychiatric services. Med Care. 2003;41(4):560-70. [pmid: 12665719].
Donald M, Dower J, Kavanagh D. Integrated versus non-integrated management and care for clients with co-occurring mental health and substance use disorders: a qualitative systematic review of randomised controlled trials. Soc Sci Med. 2005;60(6):1371-83. [pmid: 15626531].
Drew L, Delacy F. Improving the general health of persons with psychosis. Australas Psychiatry. 2007;15(4):320-3. [pmid: 17612886].
Druss BG, Zhao L, von Esenwein SA, et al. The Health and Recovery Peer (HARP) Program: A peer-led intervention to improve medical self-management for persons with serious mental illness. Schizophr Res. 2010.
Essock SM, Frisman LK, Kontos NJ. Cost-effectiveness of assertive community treatment teams. Am J Orthopsychiatry. 1998;68(2):179-90. [pmid: 9589757].
Essock SM, Kontos N. Implementing assertive community treatment teams. Psychiatr Serv. 1995;46(7):679-83. [pmid: 7552558].
Essock SM, Mueser KT, Drake RE, et al. Comparison of ACT and standard case management for delivering integrated treatment for co-occurring disorders. Psychiatr Serv. 2006;57(2):185-96. [pmid: 16452695].
Forsberg KA, Björkman T, Sandman PO, et al. Physical health--a cluster randomized controlled lifestyle intervention among persons with a psychiatric disability and their staff. Nordic Journal of Psychiatry. 2008:486-95. [pmid: 18843564].
Harvey SB, Newton A, Moye GA. Physical health monitoring in schizophrenia: The use of an invitational letter in a primary care setting. Primary Care & Community Psychiatry. 2005;10(2):71-74.
Jerrell JM, Ridgely MS. Gender differences in the assessment of specialized treatments for substance abuse among people with severe mental illness. J Psychoactive Drugs. 1995;27(4):347-55. [pmid: 8788691].
Kahn LS, Fox CH, Carrington J, et al. Telephonic nurse case management for patients with diabetes and mental illnesses: a qualitative perspective. Chronic Illn. 2009;5(4):257-67. [pmid: 20156943].
Kalichman SC, Sikkema KJ, Kelly JA, et al. Use of a brief behavioral skills intervention to prevent HIV infection among chronic mentally ill adults. Psychiatr Serv. 1995;46(3):275-80. [pmid: 7796217].
Katon WJ. The development of a randomized trial of consultation-liaison psychiatry trial in distressed high utilizers of primary care. Psychiatr Med. 1991;9(4):577-91. [pmid: 1749840].
Kemp DE, Gao K, Chan PK, et al. Medical comorbidity in bipolar disorder: Relationship between illnesses of the endocrine metabolic system and treatment outcome. Bipolar Disorders. 2010;12(4):404-413. [pmid: 20636638].
Kwon JS, Choi J-S, Bahk W-M, et al. Weight Management Program for Treatment-Emergent Weight Gain in Olanzapine-Treated Patients With Schizophrenia or Schizoaffective Disorder: A 12-Week Randomized Controlled Clinical Trial. J Clin Psychiatry. 2006;67(4):547-553. [pmid: 16669719].
Madhusoodanan S, Moise D, Sajatovic M. Schizoaffective disorder in the elderly. French DP, editor. Schizophrenic psychology: New research. Hauppauge, NY US. Nova Science Publishers. 2006:57-82.
Malla AK, Norman RM, McLean TS, et al. An integrated medical and psychosocial treatment program for psychotic disorders: patient characteristics and outcome. Can J Psychiatry. 1998;43(7):698-705. [pmid: 9773219].
McKibbin CL, Golshan S, Griver K, et al. A healthy lifestyle intervention for middle-aged and older schizophrenia patients with diabetes mellitus: A 6-month follow-up analysis. Schizophr Res. 2010;121(1–3):203-206. [pmid: 20434886].
Ohlsen RI, Peacock G, Smith S. Developing a service to monitor and improve physical health in people with serious mental illness. J Psychiatr Ment Health Nurs. 2005;12(5):614-9. [pmid: 16164514].
O’Kearney R, Garland G, Welch M, et al. Factors predicting program fidelity and delivery of an early intervention program for first episode psychosis in rural Australia. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 2004;3(2).
Pirraglia PA, Biswas K, Kilbourne AM, et al. A prospective study of the impact of comorbid medical disease on bipolar disorder outcomes. J Affect Disord. 2009;115(3):355-359. [pmid: 18930558].
Poulin M-J, Chaput J-P, Simard V, et al. Management of antipsychotic-induced weight gain: Prospective naturalistic study of the effectiveness of a supervised exercise programme. Aust N Z J Psychiatry. 2007;41(12):980-989. [pmid: 17999270].
Ridgely MS, Morrissey JP, Paulson RI, et al. Characteristics and activities of case managers in the RWJ Foundation Program on chronic mental illness. Psychiatr Serv. 1996;47(7):737-43. [pmid: 8807688].
Rivera JJ, Sullivan AM, Valenti SS. Adding consumer-providers to intensive case management: does it improve outcome?. Psychiatr Serv. 2007;58(6):802-9. [pmid: 17535940].
Robson MH, France R, Bland M. Clinical psychologist in primary care: controlled clinical and economic evaluation. Br Med J (Clin Res Ed). 1984;288(6433):1805-8.
Rubin AS, Littenberg B, Ross R, et al. Effects on processes and costs of care associated with the addition of an internist to an inpatient psychiatry team. Psychiatr Serv. 2005;56(4):463-7. [pmid: 15812098].
Ryan T, Hatfield B, Sharma I. Outcomes of referrals over a six-month period to a mental health gateway team. J Psychiatr Ment Health Nurs. 2007;14(6):527-34. [pmid: 17718724].
Sartorius N, Ustun TB, Costa e Silva JA, et al. An international study of psychological problems in primary care. Preliminary report from the World Health Organization Collaborative Project on ‘Psychological Problems in General Health Care’. Arch Gen Psychiatry. 1993;50(10):819-24. [pmid: 8215805].
Sata M, Yoshitake K, Utsunomiya H, et al. Factors affecting disability in patients attending the internal medicine departments of general hospitals. Psychiatry Clin Neurosci. 1999;53(6):611-20. [pmid: 10687740].
Schmidt-Kraepelin C, Janssen B, Gaebel W. Prevention of rehospitalization in schizophrenia: results of an integrated care project in Germany. European Archives of Psychiatry and Clinical Neuroscience. 2009;259(Suppl 2):S205-12. [pmid: 19876680].
Sim K, Chan YH, Chua TH, et al. Physical comorbidity, insight, quality of life and global functioning in first episode schizophrenia: A 24-month, longitudinal outcome study. Schizophr Res. 2006;88(1–3):82-89. [pmid: 16904871].
Simon GE, Ludman EJ, Bauer MS, et al. Long-term effectiveness and cost of a systematic care program for bipolar disorder. Arch Gen Psychiatry. 2006;63(5):500-8. [pmid: 16651507].
Snyder K, Dobscha SK, Ganzini L, et al. Clinical outcomes of integrated psychiatric and general medical care. Community Ment Health J. 2008;44(3):147-54. [pmid: 18071900].
Symonds D, Parker R. The Top End Mental Health Services General Practice Clinic: an initiative for patients with serious mental illness. Australas Psychiatry. 2007;15(1):58-61. [pmid: 17464637].
Taborda JG, Bordignon S, Bertolote JM, et al. Heart transplantation and schizophrenia. Psychosomatics. 2003;44(3):264-5. [pmid: 12724514].
Thompson WK, Kupfer DJ, Fagiolini A, et al. Prevalence and Clinical Correlates of Medical Comorbidities in Patients With Bipolar I Disorder: Analysis of Acute-Phase Data From a Randomized Controlled Trial. J Clin Psychiatry. 2006;67(5):783-788. [pmid: 16841628].
Welch K. GPs have a central role in managing schizophrenia. Practitioner. 2009;253(1718):19-23. [pmid: 19517681].
Wright CA, Osborn DP, Nazareth I, et al. Prevention of coronary heart disease in people with severe mental illnesses: a qualitative study of patient and professionals’ preferences for care. BMC Psychiatry. 2006;6:16. [pmid: 16630335].