# PEER REVIEW COMMENTS/AUTHOR RESPONSES

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes | Acknowledged
2 | Yes. The report is very clear. | Thank you.
3 | Yes | Acknowledged
4 | Yes | Acknowledged
5 | Yes | Acknowledged
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No | Acknowledged
2 | No | Acknowledged
3 | No | Acknowledged
4 | No. It is interesting that three out of the four RCTs were VA studies. While I don’t think this indicates bias, I think it does reflect the high quality research being conducted in VA and the cutting-edge nature of what VA does. I’m not sure I agree with the statement that this might impact the applicability of the findings to a non-VA setting, although I appreciate the authors’ sensitivity to this issue. The fact that two of the four studies included people with bipolar disorder exclusively is a significant limitation, as was pointed out in the review but gives clear direction for future research and emphasizes the need for VA to use a clear definition for “serious mental illness.” | Thank you.
5 | No | Acknowledged
Question 3: Are there any studies of interest to the VA that we have overlooked?
1 | Not sure: check this one (I will attach pdf to response email): Miller AL, Crismon ML, Rush AJ, et al. The Texas Medication Algorithm project: Clinical results for schizophrenia. Schizophr Bull. 2004;30(3):627–647. | Thank you for the suggestion, but the Miller study would not have met our inclusion criteria for two reasons:; 1. The intervention did not meet our definition for integrated care.; 2. The purpose was to improve symptoms of schizophrenia, not medical outcomes. The only nonpsychological measure is the SF-12.
2 | No. Not to my knowledge | Acknowledged
3 | Yes. Zappe C, Danton W. Integrated mental health and primary care: a model of coordinated services. Federal Practitioner, 2004. June: 74–81. McGuire J, Gelberg L, Blue-Howells J, Rosenheck RA. Access to primary care for homeless veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services. Adm Policy Ment Health, 2009. 36(4): 255–64. Note: neither meets criteria (first for design, 2nd for proportion of participants with SMI) but might be listed under those reports reviewed but not included | Thank you for the suggestions. The Zappe study did not come up in our literature search because it is not an RCT or other included study design. The McGuire study was found in our literature review but was excluded at the abstract level for population not of interest due to substance abuse. Per systematic review standard protocol, it was not included in the table of excluded studies because it was not reviewed at the full-text level.
4 | No | Acknowledged
5 | Yes. This is likely, given the current interest in PACT and special populations. The review methodology clearly disqualified QI studies in favor of RCTs. While this has scientific merit, it risks overlooking important and usually unfunded pre/post studies. It is, of course, difficult to get Qi projects published, so the search for successful interventions would be difficult and at variance from the usual processes and definitions of “evidence synthesis.” | We agree that valuable information may be contained in quality improvement evaluations of interventions, many of which do not get published. For the purposes of this review, we used the study criteria recommended in the Cochrane Effective Practice and Organization of Care Search. The established criteria for the evidence synthesis included study designs in addition to RCTs; however, we did not identify any non-RCT studies that met the established criteria.
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | 1. Overall very nice job—hard digging for a few nuggets. Important that you point this out to the field. I particularly like that you have policy/funding directives at the end that are fairly specific, not just “more research is needed.” I also like that you list the excluded studies. It allowed me to cross-check our own review quickly and see if there was anything we got that you didn’t. It’s also great that you list the clinicaltrials. gov list of trials in progress so we can watch for “coming attractions.” | Thank you.
1
1 | 2. Related to this, you have on p 13 a separate section on “Rating the Body of Evidence” but I don’t see that as an integral and major part of your Recommendations on p 36. I may have missed it, but this may be because it needs further highlighting. | Text has been added to the Summary and Discussion section about the rating of evidence.
1
1 | 3. You may want to consider adopting the PRISMA reporting system for your ESPs: Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: Explanation and elaboration. J Clin Epidemiol. 2009;62(10):e1–34; you get the info mostly there but PRISMA is becoming the standard (eg, by JAMA) | Acknowledged
1
1 | 4. It seems that a very key and important issue is that “None of the four trials provided information on general medical outcomes” (p 29 para 3). It seems this should be the #1 focus for future research. I’m not so concerned that a wide variety of care models haven’t been tested—it’s a good thing that we can build off of one so strongly supported as the CCM. But at this point we really have no idea whether we can make a dent in the deficits that motivated this review in the first place: premature mortality and poor medical outcome. | We agree and have addressed this point in the first paragraph of the Recommendations for Future Research section.
1
1 | 5. There is a misstatement on p 29 in para 4 (that is not consistently made in the document but should be corrected here: “Three of the four studies (54–56, 58, 60) evaluated interventions implemented at only one site.” References 55, 56, and 58 refer to an 11-site, 3-year RCT. | The reviewer is correct. We simply referenced the wrong study as being the third of the three studies conducted at one site. The two Druss studies are correct. We have replaced the references with Kilbourne 2008.
1
1 | 6. The exclusion of PTSD as an SMI seems to me to be influenced by programmatic/policy perspectives rather than clinical. To wit: The VA counts as SMI bipolar spectrum and schizophrnenia spectrum disorders, but not PTSD; the latter has its own tracking system, clinical programs, and champions who by and large differ from those committed to SMI. However, clinically, PTSD is also typically treated in the specialty MH sector, and medication such as second generation antipsychotics which can worsen medical health are used widely. Thus PTSD is characterized by both fragmentation of care and elevated iatrogenic medical risk. Additionally, more Veterans with PTSD are treated annually by VHA (~300K) than with bipolar disorder (~100K) or schizophrenia (~90K) at last count. On the other hand, most published data on “SMI” focus on the narrower definition that you adopt. | We agree that PTSD is an extremely important diagnostic entity, particularly in the VA, and acknowledge the similarities with the disorders emphasized in this review. Diagnostic inclusion criteria were informed by the views of our identified stakeholders. Two of the included studies did have subjects with PTSD.
1 | In either event, if you go back and look for PTSD it’s not likely you’ll find any studies, although this one may make it: Zatzick D, Roy-Byrne P, Russo J, et al. A randomized effectiveness trial of stepped collaborative care for acutely injured trauma survivors. Arch Gen Psychiatry. 2004;61(5):498. | The study cited in the comment is on subjects with PTSD due to physical assault. Some are hospitalized. A good proportion have substance abuse. There are no medical outcomes. While it is an important study, it does not meet the criteria established for this review.
1
1 | 7. It is likely worth noting that CCMs have begun to enter the clinical practice guideline literature as a fundamental approach to care for SMI—specifically bipolar disorder. Here are two instances, and I believe the draft of the American Psychiatric Association Guideline for bipolar disorder will cite the model as well: VA-DoD: Department of Veterans Affairs & Department of Defense. Clinical practice guideline for management of bipolar disorder in adults, version 2.0. Department of Veterans Affairs Office of Quality and Performance & US Army MEDCOM Quality Management Division. 2009. CANMAT: Yatham LN, Kennedy SH, O’Donovan C, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) guidelines for the management of patients with bipolar disorder: Update 2007. Bipolar Disord. 2006;8(6):721–739 | We have added mention of these guidelines in the summary and discussion of KQ 4.
2 | No specific suggestions/comments. | Acknowledged
3 | The report is surprisingly lengthy given the paucity of literature on the topic. It is, however, comprehensive, and detailed on the information that is available. A less restrictive selection strategy may have allowed for more comment (though perhaps in a less definitive manner) on “real world” application of these care models (see 5th item on Table 8, page 29). | Acknowledged
4 | While I understand the definition of “integrated care” used in the review, I would not have included “health coach/educator,” especially when it comes to providing primary care to individuals with SMI. From my experience, such providers are unprepared to work with individuals with highly complex mental health needs. In addition, “coordinate and follow through” services are qualitatively different from directly providing primary care services in specialty mental health or mental health services in primary care. Including a “health coach/educator” in the definition unnecessarily complicates the issue. | We agree that working with individuals with SMI requires a complex set of skills. The type of health professionals noted in this comment would not provide primary care services to the exclusion of other team members in the models included. We defined the features of integrated care using the chronic care model and medical home model as guides. Therefore, our inclusion criterion for the intervention was, “… meets definition for integrated care with the explicitly stated goal of improving general medical outcome(s). At a minimum, integrated care must: (1) Involve system redesign such that care providers are added to directly address or coordinate mental and general medical care. Examples include: adding a general medical provider (PA, APN, MD) to the mental health setting, adding a behavioral health specialist who can address multiple behaviors related to general medical care … or a health coach/educator/nurse to coordinate and follow through on general medical care with providers located outside the mental health specialty setting …”
4 | The future directions section seems very much on target. Just as studying the addition of primary care services to Assertive Community Treatment programs could yield interesting findings, so too could the addition of primary care services to Psychosocial Rehabilitation and Recovery Centers, which is another piece of the continuum of care from inpatient to outpatient care. This review is very timely, as OMHS is working to define the interaction of primary care and specialty mental health. | Thank you. We have added mention of PRRCs to the Recommendations for Future Research section.
5 | KQ 4 is the most important question for a developing field of knowledge. RCT evidence to date is so limited that it is difficult to make any conclusions other than “we need to know more.” These studies have demonstrated that directly addressing general medical needs in the mental health setting is associated with better processes of care that should lead to better outcomes (we also know that improved health outcomes may not be apparent in the timeline associated with RCTs). Given the dearth of information, the literature to date can best be used to confidently state that doing something is better than doing nothing. | We agree with the points in this comment.
5 | Given the variability (Kilbourne, Post et al. 2008) in defining “Serious Mental Illness,” we need agreement about a research definition of the term that can be applied across future studies.
5 | The review notes, but does not emphasize the apparent lack of focus on providing PCMH services within existing/developing PCMH (PACT) programs. Does this imply an assumption that it cannot be done? Are there specific interventions that can assure that patients with SMI can receive care in a VA PACT? Creating SMI PACTS in VA mental health services may be possible in a research environment but is likely to be financially unsustainable. SCAN/ECHO is a model that suggests that, with the right supports/education/mentoring in place, general medical practices can successfully treat complex populations. | We do not assume that PACT cannot successfully address the needs of individuals with SMI. The studies reviewed had a treatment-as-usual condition that was not consistent with PACT even though 3 of 4 studies did occur in the VA. We have added text to the KQ 1 discussion to reflect uncertainty about whether PACT can work with individuals with SMI.
5 | There is also need to explore models useful in CBOCs. Many CBOCs, by virtue of their small size, have developed fully integrated care programs, though without calling them programs. There is likely a wealth of information about what has been helpful, that could help identify interventions that could then be tested in RCTs. | We have added some discussion of CBOCs in the Recommendations for Future Research section.
Question 5. Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | The Mental Health QUERI SMI Health Work Group will be very interested in this (Dr. Williams is a member so I’m sure they will be in the loop). | Acknowledged
2 | As the report indicates, this evidence synthesis is highly relevant to the Patient Centered Medical Home (PACT) initiative. This report will be immensely useful to the strategic planning of the Mental Health QUERI SMI Health Workgroup. | Thank you.
3 | Not directly | Acknowledged
4 | No comment | Acknowledged
5 | The Primary Care – Mental Health Integration program has had its lens focused almost entirely on provision of MH services in PC. These services have been mostly limited to care of common, relatively straightforward psychological, psychiatric and social problems. This report may be helpful in expanding those horizons. Likewise, the added emphasis on the patient population most likely to negatively impact on any given PACT performance measure will be important. The studies reviewed note very specific target conditions, which are good fodder for local QI initiatives | Acknowledged
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | 1. CCMs per se are really not on the radar of OMHS and this report indicates that they should be.; 2. This report also highlights the need for better tracking of quality of care processes for SMI Veterans. Specifically, there have been overlapping/colliding efforts across OMHS and OQP to develop performance measures around metabolic monitoring and SMI (with/without antipsychotic use). Amy Kilbourne was leading this nascent effort that I think has, unfortunately, died on the vine. I would hope that the recommendations of this report might reinvigorate this effort. | Acknowledged
2 | No revisions are needed. | Thank you.
3 | Unfortunately, the literature review suggest benefits but, as laid out clearly in the report, there are many gaps remaining in knowledge on this topic. | Acknowledged
4 | No comment | Acknowledged
5 | Like the AHRQ funded reports a few years ago, cautioning against “premature orthodoxy” is important. | We have added text to address this in the KQ 4 discussion.
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Not sure who you are already going to contact. The Usual Suspects probably include MH QUERI and OMHS. Diabetes QUERI and related medically oriented QUERIs also come to mind. OQP (or whatever it’s called now) Grant Huang the head of CSP, since you recommend a CSP-level trial The SMI Committee in particular under OMHS Outside VA: NAMI and the Depression & Bipolar Support Alliance | Thank you for the suggestions. We will disseminate the report in these directions.
2 | I believe the key stakeholders have already been included in developing this report, including OMHS, HSR&D/QUERI, and Mental Health QUERI. The Primary Care-Mental Health Integration Initiative and PACT leaders should be made aware if they are not already on the list. | Thank you for the suggestions. We will disseminate the report in these directions.
3 | No comment | Acknowledged
4 | No comment | Acknowledged
5 | Jeff Burk, national director of psychosocial rehab and recovery is vital to this area. If not al-ready reviewing, he should be added | Thank you for the suggestion. Dr. Burk was a reviewer of this report. We will make sure he is aware of the final report.