# CRITERIA USED IN QUALITY ASSESSMENT

Criteria Used in Qualtiy Assessment

### General Instructions

For each risk of bias item, rate as “Yes,” “No,” or “Unclear.” After considering each of the quality items, give the study an overall quality rating of good, fair, or poor.

### Detailed Quality Items

If an item is rated as “No,” describe why in the comments column.

1. [underlined: Randomization adequate?] Was the allocation sequence adequately generated? Yes/No/Unclear
2. [underlined: Allocation concealment adequate?] Was allocation adequately concealed? Yes/No/Unclear
3. [underlined: Incomplete outcome data adequately addressed?] Yes/No/Unclear Consider Attrition bias: Were there systematic differences between groups in withdrawals from a study or high overall loss to followup? (Even small differences could be important when rates are low.) Were subjects excluded from the analysis – if so, were the exclusions sensible?
4. [underlined: Subjects Blinded?] Were subjects blind to treatment assignment? Yes/No/Unclear
5. [underlined: Outcome assessor blinded?] (This may be recorded separately for each critically important outcome.) Were Outcome assessors blind to treatment assignment? Yes/No/Unclear
6. [underlined: Provider (treating clinician) blinded?] Were providers blind to treatment assignment? Yes/No/Unclear
7. [underlined: All outcomes reported?] Are reports of the study free of suggestion of selective outcome reporting (systematic differences between reported and unreported findings)?Yes/No/Unclear
8. [underlined: Intention-to-treat analysis?] Yes (all eligible patients that were randomized are included in analysis; note- mixed models and survival analyses are in general ITT)/No/Unclear
9. [underlined: Adequate power for main effects?] Yes (if power analysis or sample size calculation given and recruitment met needs or if post-hoc power calculation shows adequate power)/No (did not meet projected sample size needs)/Unclear (no power or sample size calculation given)
10. [underlined: Other Selection bias?] Were there methods that could lead to differences or were there systematic differences observed in baseline characteristics and prognostic factors of the groups compared?(e.g., failure of randomization): Yes/No/Unclear
11. [underlined: Comparable groups maintained?] (Includes crossovers, adherence, and contamination.) Consider issues of crossover (e.g., from one intervention to another), adherence (major differences in adherence to the interventions being compared), contamination (e.g., some members of control group get intervention) Yes/No/Unclear
12. [underlined: Lack of Performance bias?] Were there no important systematic differences in the care that was provided, other than the intervention of interest? Yes/No/Unclear
13. [underlined: Lack of Measurement bias?] Were the measures used reliable and valid – and therefore, “yes” no important measurement bias? Yes/No/Unclear
14. [underlined: Absence of Detection bias?] Were there systematic differences between groups in how outcomes are determined? If no systematic differences answer “yes” – no important detection bias. Yes/No/Unclear
15. [underlined: Was there the absence of potential important conflict of interest?] The focus here is financial conflict of interest. Therefore if no financial conflict of interest (e.g. funded by government or foundation and authors do not have financial relationships with drug/device manufacturer), then answer “yes.” Yes/No/Unclear

### Overall rating

Please assign each study an overall quality rating of “Good,” “Fair,” or “Poor” based on the following definitions:

- A “Good” study has the least bias, and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
- A “Fair” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
- A “Poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

Table 11 Quality assessment for the four RCTs

Quality item | Druss et al., 2001 | Bauer et al., 2006 and Kilbourne et al., 2009 | Kilbourne et al., 2008 | Druss et al., 2010
1. Randomization adequate? | Yes | Yes | Yes | Yes
2. Allocation concealment adequate? | Unclear | Unclear | Yes | Yes
3. Incomplete outcome date adequately addressed? | Yes | Yes | Yes | Yes
4. Subject blinded? | No | No | Yes | No
5. Outcome assessor blinded? | Unclear | Unclear | Yes | Yes
6. Provider blinded? | No | No | No | No
7. All outcomes reported? | Yes | Yes | Yes | Yes
8. Intention-to-treat analysis? | Yes | Yes | Yes | Yes
9. Adequate power for main effects? | Unclear | Yes | Unclear | Unclear
10. Other selection bias? | Yes | Yes | Yes | Yes
11. Comparable groups maintained? | Yes | Yes | Yes | Yes
12. Lack of performance bias? | Yes | Yes | Yes | Yes
13. Lack of measurement bias? | Yes | Yes | Yes | Yes
14. Absence of detection bias? | Yes | Yes | Yes | Yes
15. Was there the absence of potential important conflict of interest? | Yes | Yes | Yes | Yes