# STUDY SELECTION FORM

## Criteria for inclusion and exclusion of studies

### Inclusion criteria

- Study designs recommended by the Cochrane Effective Practice and Organization of Care Group (does NOT include cross-over or observational):
  ○ Patient or cluster RCTs
  ○ Nonrandomized cluster controlled trials: An experimental study in which practices or clinicians are allocated to interventions using nonrandom methods
  ○ Controlled before-and-after studies: A study in which observations are made before and after the implementation of an intervention, both in a group that receives the intervention and in a control group that does not
  ○ Interrupted time series designs: A study that uses observations at multiple time points before and after an intervention – an attempt to detect if the intervention has had an effect significantly greater than any underlying trend over time
- Sample population has schizophrenia, schizoaffective disorder and/or bipolar disorder, or meets the definition of SMI based on low functional status and least 25% are diagnosed with schizophrenia, schizoaffective disorder and/or bipolar disorder.
- Sample population age 18 and over
- Outpatient population (from mental health clinics and satellite clinics, not community sites)
- Intervention or “exposure” meets definition for integrated care with the explicitly stated goal of improving general medical outcome(s). At a minimum, integrated care must:
  ○ Involve system redesign such that care providers are added to directly address or coordinate mental and general medical care. Examples include: adding a general medical provider (PA, APN, MD) to the mental health setting, adding a behavioral health specialist who can address multiple behaviors related to general medical care or a health coach/educator/nurse to coordinate and follow through on general medical care with providers located outside the mental health specialty setting.
  ○ If system redesign with care providers is not used, there must be at least 3 of the following elements designed to provide integrated mental and general medical care (decision support, information systems, self-management support, teams care or enhanced communication).
- Includes results on at least one of the relevant outcomes (KQs 1–3)
- Study duration of at least 3 months
- Must be in a peer-reviewed publication
- English language
- Study conducted in North America, Western Europe, Australia/New Zealand

### Exclusion criteria

- Non-English language publication
- Cross-sectional studies and other observational study designs not specifically listed as “included” study designs
- Studies in which the sample is selected for individuals with substance abuse disorders
- Community, rather than practice-based interventions (i.e., not interested in senior centers, but what can be achieved within existing VA clinics and satellite facilities)
- Interventions designed to affect only one specific outcome or aspect of general medical health (e.g., weight loss or smoking cessation, etc.)
- Interventions that involve only: self-management support, enhanced information systems (e.g. EMR, shared records), decision support (e.g., clinical guidelines, clinical reminders) or enhanced access (e.g., location closer to target population or open access scheduling).