# SEARCH STRATEGY

Step | Category | Terms | Result
1 | Eligible disorders | (“Serious mental illness”) [all fields] OR (“severe mental illness”) [all fields] OR schizophrenia [tiab] OR schizophrenia [mesh] OR bipolar disorder [mesh:noexp] OR bipolar disorder [tiab] OR psychotic disorders [mesh:noexp] OR psychotic disorders [tiab] OR schizoaffective disorder* [tiab] OR mania [tiab] OR manic [tiab] OR bipolar affective disorder [tiab] OR *mental disorders [tiab] | 790929
2 | Interventions | Delivery of Health Care, Integrated [Mesh] OR Patient Care Team [Mesh] OR Patient Care Planning [Mesh] OR Disease Management [Mesh] OR Comprehensive Health Care [Mesh:noexp] OR Patient Care Management [Mesh:noexp] OR Primary Health Care [Mesh] OR Internal Medicine [Mesh] OR Family practice [Mesh] OR Geriatrics [Mesh] OR “general practice” [ti] OR (“continuity of care” OR “coordinated care” OR “coordinated program*” OR “team care” OR “team treatment” OR “team assessment” OR “team consultation”) OR (collaborat*[ti] AND care [ti]) OR “shared care” [ti] OR (collaborat*[ti] AND manage*[ti]) | 292051
3 | Study designs | (“pre-post” [tiab] OR “pre test” [tiab] OR “pre-test” [tiab] OR “pretest” [tiab] OR “post test” [tiab] OR “post-test” [tiab]) OR ((before[tiab] AND after [tiab]) OR (before [tiab] AND during [tiab])) OR (quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom* [tiab] OR quasi random*[tiab] OR quasicontrol* [tiab] OR quasi control* [tiab]) OR (“time series” [tiab] AND interrupt* [tiab]) OR (“time points” [tiab] AND (multiple[tiab] OR three[tiab] OR four[tiab] OR five[tiab] OR six[tiab] OR seven[tiab] OR eight[tiab] OR nine[tiab] OR ten[tiab] OR month*[tiab] OR hour*[tiab] OR day*[tiab])) OR (“process assessment (health care)” [MeSH Terms] OR program evaluation [mesh]) OR ((clinical [tiab] AND trial [tiab]) OR clinical trials [MeSH Terms] OR clinical trial [Publication Type] OR random*[tiab] OR random allocation [MeSH Terms] OR therapeutic use [MeSH Subheading]) | 3564636
4 | Combine results | #1 AND #2 AND #3
5 | Apply limits | LIMITS: English and Human and Adult | 1058