# SUMMARY AND DISCUSSION

Our systematic review compared outcomes associated with 3 key questions: 1) use of non-SSP providers compared to SSPs; 2) electronic consultation compared to interactive consultation; and 3) in-home APAP compared to in-laboratory CPAP. Overall the evidence was often lacking to fully address the key questions and we found no data for Key Question 2.

For Key Question 1, we found 8 studies, of which 4 were randomized trials. Access to care was not reported in any of the studies, so we were unable to determine if use of non-SSP providers improves access to OSA diagnosis and treatment. Likewise, adverse events including overdiagnosis/overtreatment and underdiagnosis/undertreatment were not reported. We found moderate-strength evidence that care provided by non-SSP providers and SSPs resulted in similar Epworth Sleepiness Scores, quality of life, and treatment compliance.

For Key Question 3, we found 4 studies comparing at-home APAP to in-laboratory CPAP for titration of CPAP pressures and 23 for treatment. For both titration and treatment, access to care was not reported in any of the studies. Adverse events were rarely reported and therefore strength of evidence was insufficient to low to determine whether at-home APAP and in-laboratory CPAP differ for adverse events. We found moderate-strength evidence in both titration and treatment studies that at-home APAP and in-lab CPAP were similar in regards to Epworth Sleepiness Scores and quality of life outcomes. For PAP titration, at-home APAP and in-laboratory CPAP resulted in similar treatment compliance, though strength of evidence was low. For PAP treatment, at-home APAP and in-laboratory CPAP resulted in similar treatment compliance (moderate strength of evidence).

Our systematic review was not intended to determine the best OSA screening tools nor in whom OSA treatments are most effective. However, most of the included studies in our report enrolled patients who were generally older, obese, and sleepy, as determined by Epworth Sleepiness Scores. Furthermore, 2 recent evidence reports and clinical practice recommendations have addressed OSA screening and treatment.^12–15^ This additional evidence may assist clinicians and policymakers when determining referral recommendations and evaluation pathways to target individuals with the greatest likelihood of benefiting while minimizing harms, as well as financial and opportunity costs associated with diagnosis and treatment of OSA. Specifically, a prior evidence report and accompanying clinical practice guideline by the ACP recommends that clinicians target their assessment of OSA to individuals with unexplained daytime sleepiness. The ACP concluded that assessment of OSA in the absence of daytime sleepiness or treatment of persons with low AHI scores is low-value care because evidence to date indicates that neither improves clinical outcomes.^14^ Additionally, a draft evidence report and recommendation statement from the U.S. Preventive Services Task Force indicates that evidence is insufficient to assess the net benefit of screening for and treatment of asymptomatic OSA.^15^ While good evidence has established that people with severe OSA are at increased mortality risk compared to controls, trials of CPAP and other treatments have not established whether treatment reduces mortality or improves most other health outcomes, except possibly for sleep-related quality of life. In addition to the findings included in the ACP and USPSTF reports, a recently published multi-site randomized trial showed that CPAP was not effective for secondary prevention of cardiovascular events in those with established cardiovascular disease and moderate to severe OSA.^16^ Furthermore, the USPSTF evidence report also found uncertainty about the clinical utility of screening tools and that most screening questionnaires had poor diagnostic accuracy.

When redesigning OSA care models we recommend that clinicians and policymakers consider the limited data to support some of these newer models (eg, hiring non-SSPs to provide sleep care) and the existing evidence used to inform clinical practice recommendations by the ACP and USPSTF. While the existing data do not suggest significant harm from these newer care models, current data are insufficient to draw firm conclusions.

## LIMITATIONS

Inherent to the process of systematic review there are certain general limitations, some related to our inclusion criteria, others inherent in the available research. For example, we limited inclusion to English language studies and those performed in the United States, Canada, Western Europe, Australia, or New Zealand. We did this to target research most likely to be applicable to clinical practice in the United States and Veterans Affairs facilities. However, these search criteria also mean that our findings may not apply to the evaluation and care of OSA patients in other healthcare settings.

We also chose to exclude studies of dentists and anesthesiologists due to our uncertainty whether or not these persons truly represent “Non-Sleep-Specialist Physicians” given that many dentists and anesthesiologists have substantial practices or background in sleep medicine. Therefore, our systematic review does not address the role of these practitioners on sleep apnea care. We also did not assess the role of surgery or mandibular assist devices for OSA treatment including referral of patients who may be more interested in or better candidates for these options.

A significant limitation is the paucity of high-quality literature regarding key questions 1 and 2. For initial evaluation and treatment of OSA (Key Question 1), we identified 4 randomized trials and 4 observational studies. The non-SSP providers were primary care providers in 4 studies, nurses in 3 studies, and a pulmonologist in one study. Therefore, although we are aware of the existence of clinical care models utilizing sleep respiratory therapists to provide varying degrees of OSA care, we did not find any studies to address this particular type of practitioner. Due to small sample sizes, we were also unable to directly compare primary care-based models of OSA evaluation and treatment to sleep nurse-based models.

We also note that, importantly, the providers in many of these “primary care” studies were persons who had substantial experience in sleep medicine. For example, in the randomized trial of Chai-Coetzer and colleagues,^31^ one of the 4 primary care nurses had 15 years of experience at a tertiary care sleep medicine center. In the study by Chamorro and colleagues,^32^ the non-SSP provider was a ‘primary care pulmonologist’ – the degree of sleep training and experience of this person was unclear. Therefore, the generalizability of these findings to primary care providers with less experience in sleep medicine is not clear.

Due to the lack of studies regarding electronic consultation for persons suspected of having OSA (Key Question 2), we are unable to determine the effectiveness/harms/resource utilization of this evolving practice.

We found the most data for Key Question 3, which compared at-home autotitrating continuous positive airway pressure (APAP) to the more traditional CPAP titrated in the PSG laboratory. Several studies that compared at-home APAP to in-lab CPAP^63–65^ were excluded as these studies also used different methods of diagnostic testing (eg, HST preceded at-home APAP, while PSG preceded in-lab CPAP) and we were concerned that the differences in diagnostic testing might confound our analysis of outcomes between APAP and CPAP. Although these studies were not included in our formal analysis, they reassuringly also further support the notion that APAP and CPAP (combined with at-home vs in-laboratory testing, respectively) result in similar outcomes in regards to: 1) 6-week ESS and PAP adherence among 106 Veterans in Florida using 2–3 nights of APAP for titration,^63^ 3-month ESS, SF-12, and adherence among 182 Veterans in Pennsylvania using 4–5 nights of APAP for titration,^64^ and 3-month ESS and SF-36 among 142 patients at 7 academic sleep centers in the U.S. using 5–7 nights of APAP for titration;^65^ this last study also found higher 3-month PAP adherence in those assigned to the home study plus APAP titration arm.^65^

## APPLICABILITY AND IMPLEMENTATION OF FINDINGS

Most patients enrolled in studies were obese, middle-aged men, with severe OSA based on both high AHI levels and the presence of excessive daytime sleepiness. Our findings are most applicable to these individuals. We found only one study that was performed in a VA population for Key Question 3.^43^ One study was performed at Walter Reed Army Medical Center for key questions 1 and 3.^33^ While most studies were not specifically conducted in VA or military populations, because the patients enrolled in these studies were generally older, overweight men with OSA, we believe the findings of our systematic review should be applicable to the population of Veterans served by VA facilities.

Many of the study providers who were not SSPs had prior sleep training and therefore the results may not be fully generalizable to all primary care providers. While data are not conclusive, because our findings indicated similar Epworth Sleepiness Scores, quality of life, and treatment compliance scores among patients evaluated and treated by non-SSPs compared to SSPs, it may be reasonable to consider expanded use of non-SSP providers who have received training in sleep medicine, especially where SSPs are in limited supply and demand for OSA services is high. Similarly, greater use of at-home APAP may lessen dependence on backlogged PSG laboratories, as most health outcomes were similar between groups.

Our report focused on methods that might improve the ‘supply’ side of OSA evaluation and treatment, through use of non-SSPs, electronic consultation, and at-home APAP titration and treatment. However, healthcare systems struggling to match supply to demand might also consider whether the ‘demand’ is truly appropriate. We found little to no data in screen-detected patients (ie, those found to have abnormal AHI either through direct referral to sleep laboratories or based on results of screening questionnaires such as the Berlin questionnaire but without excessive daytime sleepiness). The evidence to date indicates that the main benefit of OSA detection and treatment is improvement in patient-reported sleepiness symptoms among those with unexplained daytime somnolence. Therefore, VA healthcare providers and decision-makers could potentially achieve the highest value care, including resource use, by targeting case finding approaches and subsequent evaluation and treatment to individuals with unexplained daytime somnolence and who express interest in further evaluation and treatment. Theorectically, this referral approach could be readily be implemented by developing and using electronic medical record templates that describe the evidence-based rationale for the referral recommendations while requesting that referring providers include information specifically about daytime somnolence and the patient’s willingness for further evaluation and treatment in the consult.

## RESEARCH GAPS/FUTURE RESEARCH

Comparative effectiveness trials were lacking for all key questions. Key questions 1 and 2 would particularly benefit from trials to address the outcomes resulting from non-SSP case finding and care of sleep apnea patients (Key Question 1) and outcomes resulting from electronic consultation (Key Question 2). Limited available data suggest that care led by non-SSPs may potentially provide equivalent outcomes to care led by SSPs. Comparative effectiveness trials are needed in order to determine whether such results can be achieved in routine practice, outside of controlled research settings. The available data suggest that with appropriate training, non-SSPs can potentially provide equivalent outcomes, but the operationalization of such training is unclear. Therefore, future comparative effectiveness trials should describe their training programs in detail. Such trials should also collect clinical outcomes where possible.

In regards to case finding, future studies should compare outcomes among differing strategies such as offering sleep studies and treatment to a broad set of patients (eg, with OSA risk factors, regardless of number of risk factors or symptoms) versus a narrow set of criteria (eg, high OSA risk or very symptomatic). Outcomes of interest in such studies would include consultation rates, sleep study rates, percent of sleep studies confirming OSA, severity of OSA, changes in sleepiness, and adherence to CPAP. Such studies might also compare case finding led by sleep specialists, primary care providers, nurses, or even automated through electronic medical record (EMR) systems.

As more healthcare systems implement comprehensive EMRs, we anticipate Key Question 2 will become more feasible to study. In the current climate of increasing numbers of sleep referrals, yet a declining number of SSPs, EMR-based electronic consultation holds significant promise to provide equivalent outcomes in a more cost-effective, time-efficient manner. Although many systems have already implemented electronic consultation systems,^66^ evidence supporting this practice is largely lacking and further studies should be conducted. We think comparative effectiveness study designs such as stepped-wedge randomization (where sites are randomly assigned to the time point at which they implement electronic consultation) would allow the creation of good-quality evidence to quantify the risks, benefits, and economic impacts of electronic consultation for patients with known or suspected OSA.

Many studies have addressed Key Question 3 and while we found similar sleepiness, quality of life, and adherence between APAP and CPAP, future studies should include longer-term follow-up to allow better determination of long-term clinical ouctomes. Future studies should also include more rigorous collection and reporting of adverse event data.

A large gap in evidence is related to the effectiveness of treatment for individuals without excessive daytime sleepiness (screen detected or case-finding in at-risk asymptomatic individuals) and on outcomes other than daytime sleepiness. For example, a recently published multi-site randomized trial showed that CPAP was not effective for secondary prevention of cardiovascular events in those with established cardiovascular disease and moderate to severe OSA.^16^ Additional information gaps include the effectiveness of treatment in those with mild AHI regardless of symptoms. These gaps are supported by recent evidence reports and accompanying clinical practice recommendations by the ACP and USPSTF and described in greater detail in the introduction and above. There are also critically important gaps to fill due to the dramatic increase in patients with, or suspected to have, OSA and thus being referred for evaluation and treatment.

## CONCLUSIONS

Among patients suspected of having OSA, evidence suggests that primary care providers and sleep-specialist nurses might provide similar outcomes to SSPs, although the strength of this evidence was only moderate and many outcomes were inconsistently reported. Likewise, among patients diagnosed with OSA, evidence suggests that at-home APAP titration and treatment provides similar outcomes to fixed pressure CPAP titrated in the PSG laboratory, although the strength of evidence was generally low to moderate.

We found no evidence addressing the topic of electronic consultation for the management of known or suspected OSA.

Future studies are needed to determine which patients derive the most benefit from treatment and should be prioritized for testing and treatment, whether newer models of care with less reliance on SSP time (either through utilization of other types of providers or electronic consultation) result in similar outcomes to traditional models, and if effective, how such models should be implemented.