# RESULTS

We reviewed 2,847 abstracts, 2,252 from MEDLINE and 595 from CINAHL. We excluded 2,493 abstracts and reviewed the full text of 354 references. During full-text review we excluded 323 articles leaving 31 eligible for inclusion. Hand searching pertinent trials and systematic review identified an additional 3 references. Figure 2 details the process.

## LITERATURE FLOW

Figure 2 Literature Flow Chart

## KEY QUESTION #1 For adults with suspected OSA, what are the effectiveness/harms/resource utilization of case finding and care provided by practitioners who are not sleep physicians (including PCPs, PAs, NPs, technologists, nurses, and respiratory therapists), compared to case finding and care provided by sleep specialist physicians?

### Summary of Findings for Key Question #1

#### Case Finding

- No studies assessed the diagnostic accuracy of non-sleep-specialist nurse for case finding and referral.
- One retrospective study reported good agreement between a primary care pulmonologist and a SSP on what sleep test to order for patients referred by their family physician.

#### Care

- Clinical (ie, patient-centered) outcomes were infrequently and inconsistently reported. When reported there was no significant difference in clinical outcomes between OSA treated by primary care/nurses and SSPs. The strength of evidence for quality of life was moderate.
- Intermediate outcomes were more commonly reported. Sleep symptom scores were similar between groups (moderate strength of evidence).
- There was little evidence that treatment compliance differed between patients treated by SSPs and those not, including the proportion of patients with 4 hours or more of CPAP use on 70% or more of nights (moderate strength of evidence).
- Very few studies reported other intermediate outcomes. One reported a significantly lower residual AHI on CPAP in patients referred for PSG by non-sleep specialists and another found that the proportion of patients receiving CPAP within one month of their PSG was significantly higher in patients cared for by a SSP. Strength of evidence for access to care and adverse events was insufficient.

#### Overview of Studies – Table 1

Table 1 Key Question 1: Study Characteristics

Characteristic | Weighted Mean (range) Unless otherwise noted | Number of studies reporting
Total number enrolled/randomized | 1,401 (65–403) | 8
Randomized controlled trials, total n | 589 (65–195) | 4
Other, total n | 812 (96–403) | 4
Primary care, total n | 564 (96–210) | 4
Sleep-specialist nurse, total n | 434 (65–195) | 3
Other non-sleep physician provider, total n | 403 | 1
Age of subjects (years) | 52.2 (47.7–58.7) | 8
Percent Male | 67% (47–85.5) | 8
Baseline BMI, kg/m^2^ | 34 (30.2–36.6) | 7
Baseline ESS | 11.5 (8.5–15.7) | 7
Baseline AHI (events/hour) | 32 (21–43) | 3
Percent with hypertension (%)^*^ | 54 (38–58.5) | 4
Location – North America, total n | 716 (103–403) | 3
Location – Europe, total n | 335 (65–174) | 3
Location – Australia/New Zealand, total n | 350 (155–195) | 2
Required participants to have daytime sleepiness, total n | 415 (65–195) | 3

* as defined by study

Eight studies (n = 1,401; 4 RCTs) reported results for KQ1.^29–36^ Study characteristics are summarized in Table 1 with more details in Appendix C, Table 1. Sleep physician care was compared to management by primary care in 4 studies (n = 564),^31–33,36^ sleep-specialist nurses in 3 studies (n = 434),^29,30,34^ and other non-sleep physicians in one study (n = 403).^35^ The weighted mean age was 52 years and roughly half of the participants (54%) had hypertension. The mean BMI was 34 kg/m^2^, ESS was 11.5, and AHI was 32/hour. Three studies (n = 678) reported that their patients had moderate or severe OSA (mean AHI ≥15/hour)^29,33,35^ and 5 studies (n = 721) reported that their patients had mild OSA (mean ESS 11–14)^30–32^ or moderate (mean ESS > 14) sleepiness.^29,33^ Three studies (n = 415) required all participants to have symptoms of sleepiness (ie, ESS ≥8^30,31^ or ESS ≥12^29^), and participants in these studies had a mean baseline ESS of 13.6 (mild sleepiness). Participants in the remaining 4 studies that reported ESS but did not require sleepiness had a mean baseline ESS of 10.5 (normal sleepiness). Three studies took place in Europe, 3 in North America, and 2 in Australia/New Zealand. Of the 4 RCTs, one was low risk of bias^30^ and 3 were medium risk of bias. Of the 4 observational studies, 3 were medium risk of bias and one was high risk of bias.^32^

### Case Finding

One retrospective study reported on the ability of a primary care pulmonologist to order the proper sleep test.^32^ Patients (n = 96) were referred to the primary care pulmonologist by their family physician. An SSP reviewed the sleep tests ordered by the primary care pulmonologist. There was good agreement between the primary care pulmonologist and SSP (kappa = .74) and 93% (89/96) of the referred patients were diagnosed with OSA.

### Care

Seven studies reported treatment outcomes in patients being treated by providers other tha SSPs. Three of these studies compared SSP care to primary care (n = 468; 1 RCT), 3 compared SSP care to sleep specialist nurses (n = 434; 3 RCTs), and one compared SSP care to management by a variety of physicians who were not sleep specialists. The nature of care provided by different professionals was varied and often inconsistently reported. Two of the studies (n = 506) were retrospective and gave few details regarding the care given by each practitioner.^35,36^ Three studies (n = 560; 2 RCTs and one cohort study) described interventions in which the SSP had much more autonomy than the non-SSP provider, who was generally giving protocol-driven care that followed clinical guidelines.^30,31,33^ Two RCTs compared patients who received similar care delivered by different providers and at different locations (home versus a hospital/clinic).^29,34^ Many of the articles only described the care given to patients in non-specific terms and often details were only given for one study arm.

#### Clinical Outcomes – Table 2; Appendix C, Tables 2–3

Table 2 Clinical Outcomes Comparing Non-sleep Specialists to Sleep Specialists

Author, Year Enrolled/Randomized (n) Study Design | All-cause Mortality | Normalization of AHI | MID | | Quality of Life | | Patient Satisfaction | | Resource Utilization | | | | Access to Care | Libido | % Achieving Target | | | | Cognitive Symptoms | Other
Author, Year Enrolled/Randomized (n) Study Design | All-cause Mortality | Normalization of AHI | ESS | Urinary Symptom Scores | SF-36 | SAQLI | VAS | VSQ-9 | Hospitalization | Treatment | Provider Contact | Referrals | Access to Care | Libido | Weight Loss | BMI | Blood Pressure | HbA1c | Cognitive Symptoms | Other
Primary Care 3 studies (n = 468)
Chai-Coetzer 2013 ^31^ (n = 155); RCT | | | | | ↔ | | | ↕ | | ↔
Lettieri 2011^33^ (n = 210); Obs. cohort
Scharf 2004^36^ (n = 103); Retro survey/chart review | | | | | | | | | | ↔ | | | | | | | | | | ↔^a^
Nurse 3 studies (n = 434)
Andreu 2012^29^ (n = 65); RCT | | | | | | | | | | | X
Antic 2009^30^ (n = 195); RCT | | | | | ↔ | | | ↔ | | | ↕
Palmer 2004^34^ (n = 174); RCT | | | | | ↔ | | | | | | ↔ | X | | | | | | | | ↔^b^
Not specified 1 study (n = 403)
Pamidi 2012^35^ (n = 403); Retro chart review
Total | 0 | 0 | 0 | 0 | 3↔ | 0 | 0 | 1↔ 1↕ | 0 | 2↔ | 1↔ 1↕ 1X | 1X | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2↔

a subjective symptom improvement,

b HADS = Hospital Anxiety and Depression Scale

MID = minimally important difference; ESS = Epworth Sleepiness Scale; BMI = body mass index; SF-36 = 36 item short form survey; SAQLI = Calgary Sleep Apnea Quality of Life Index; VAS = visual analogue scale; VSQ-9 = Visit-Specific Satisfaction Instrument; HbA1c = hemoglobin A1c; retro = retrospective; Obs = observational

↑ = significantly better with non-SSP than with usual care SSP including less resource utilization, ↔= non-significant difference between non- SSP and SSP care, ↓= significantly better with SSP than non-SSAP, ↕ = mixed results comparing non-SSP and SSP care, X = between provider significance not reported; number before symbol indicates number of studies

Light gray shading in a cell indicates measure of significance was calculated, not reported by the study.

Clinical outcomes were only reported sporadically. The most commonly reported clinical outcome was resource utilization (k = 5). Two studies reported receipt of treatment finding no significant difference in the proportion of patients using CPAP at follow-up.^31,36^ One study found that patients whose follow-up appointments were at the hospital, as opposed to at home, often needed additional help from a specialist nurse for practical problems, although the significance and impact of this finding was not reported.^34^ Three studies reported provider contact. One RCT found that patients being managed by a sleep specialist nurse had significantly more scheduled nursing time than patients being managed by a SSP (153 minutes vs 103 minutes, P<.001, effect size 1.25, 95% CI 0.94, 1.56) and patients managed by SSPs had significantly more physician visits than patients receiving nurse-led care (2.4 vs 0.2; P<.001, effect size 2.24, 95% CI 1.88, 2.60).^30^ A second RCT compared the time nurse-managed patients spent with a nurse to the time SSP-managed patients spent with a SSP and found groups were similar (effect size 0.32, 95% CI −0.13, 0.66).^34^ A third study reported extra visits and calls required by patients but without a measure of statistical significance.^29^ We had difficulty determining what would constitute improved resource utilization and ultimately, OSA management by a non-SSP had no significant effect on any measure of resource utilization as compared to SSP care.

Three studies reported quality of life and all found that SF-36 scores were similar for patients being managed by primary care (k = 1)^31^ or sleep-specialist nurses (k = 2)^30,34^ compared to SSPs. The pooled standard mean differences in change from baseline for the mental health and vitality components of the SF-36 are presented in Figure 3.

Figure 3 SF 36 Mental Health and Vitality Scores, Standardized Mean Differences in Mean Change from Baseline, Non-sleep Specialist versus Sleep Specialist^a^

^a^ Lower and upper limits represent 95% confidence intervals

PCP = primary care physician

The 2 studies reporting patient satisfaction both found no significant difference in overall satisfaction between groups.^30,31^ One study reported significant differences on several VSQ-9 items but cautioned that the effect sizes were all small and may not be clinically significant.^31^ No study reported all-cause mortality, access to care, minimally important differences in symptom scores, cognitive outcomes, libido, or percent of patients achieving physiological targets.

#### Intermediate Outcomes – Table 3; Appendix C, Tables 4–6

Table 3 Intermediate Outcomes Comparing Non-sleep Specialists to Sleep Specialists

Author, Year Enrolled/randomized (n) Study design | AHI | Oxygen Saturation | | | | Sleep Symptom Scores | | | | | | | | Weight Loss | BMI | Blood Pressure | HbA1c | Time to Initiation of Therapy | Adverse Events | Cost | Compliance/Adherence
Author, Year Enrolled/randomized (n) Study design | AHI | Mean | Time <90% | ODI | Minimum | ESS | FOSQ | SASQ | Arousals | TST | PSQI | Snoring | Other | Weight Loss | BMI | Blood Pressure | HbA1c | Time to Initiation of Therapy | Adverse Events | Cost | Hrs/night | Proportion of Nights | Regular Use ^c^ | Other
Primary Care 3 studies (n = 468)
Chai-Coetzer, 2013 ^31^ (n = 155); RCT | | | | | | ↔ | ↔ | ↔ | | | | | | ↔ | | ↔ | | | | X | ↔
Lettieri, 2011^33^ (n = 210); Obs. cohort | | | | | | ↔ | | | | | | | | | | | | | ↔ | | ↔ | ↔ | ↔
Scharf, 2004^36^ (n = 103); Retro survey/chart review | | | | | | | | | | | | | | | | | | ↓ | | | | | ↔
Nurse 3 studies (n = 434)
Andreu, 2012^29^ (n = 65); RCT | | | | | | ↔ | ↕ | | | | | | | | | | | | X | ↑^a^ | ↔ | | ↔
Antic, 2009^30^ (n = 195); RCT | | | | | | ↔ | ↔ | | | | | | ↔^b^ | | | | | ↕ | | ↑ | ↔
Palmer, 2004^34^ (n = 174); RCT | | | | | | ↔ | | | | | | | ↔ | | | | | | | X | ↔
Not specified 1 study (n = 403)
Pamidi, 2012^35^ (n = 403); Retro chart review | ↑ | | | | | | | | | | | | | | | | | | | | ↓ | | ↓
Total | 1↑ | | | | | 5↔ | 2↔ 1↕ | 1 ↔ | | | | | 2 ↔ | 1 ↔ | | 1 ↔ | | 1↓ 1↕ | 1 ↔ 1 X | 2 ↑ 2 X | 5 ↔ 1↓ | 1↔ | 3 ↔ 1↓

a decreased costs

b maintenance of wakefulness

c ≥4h of use on ≥70% of nights

AHI = apnea-hypopnea index; ODI = oxygen desaturation index; ESS = Epworth Sleepiness Scale; FOSQ = Functional Outcomes of Sleep Questionnaire; SASQ = Sleep Apnea Symptom Questionnaire;TST = total sleep time; PSQI = Pittsburgh Sleep Quality Index; BMI = body mass index; retro = retrospective; Obs = observational

↑ = significantly better with non-SSP than with usual care SSP including less resource utilization, ↔ = non-significant difference between non-SSP and SSP care, ↓ = significantly better with SSP than non-SSP, ↕ = mixed results comparing non-SSP and SSP care, X = between provider significance not reported; number before symbol indicates number of studies

Light gray shading in a cell indicates measure of significance was calculated, not reported by the study.

The most frequently reported intermediate outcome was compliance with therapy, reported by 7 studies with some reporting multiple indicators of compliance. The majority of studies reported adherence as hours of use per night (k = 6).^29–31,33–35^ Several reported the proportion of patients with regular use (k = 4), defined as ≥4 hours of CPAP use on ≥70% of nights, a compliance threshold often used to define minimally acceptable compliance for payment reimbursement.^29,33,35,36^ One reported the proportion of nights with any use.^33^ Six of the 7 studies found no difference in compliance, regardless of measure used, when comparing patients receiving SSP care to those receiving care from non-SSPs. The pooled mean difference from the RCTs was -0.25 (95% CI -0.72, 0.22; I^2^ = 21%) (Figure 4). The final study found that patients who were referred for a sleep study by non-SSPs were significantly less compliant, with fewer hours per night and less regular use, than those patients who were referred by SSPs.^35^ Cost was reported, in various ways, by 4 of the studies.^29–31,34^ Two did not report the significance of differences between SSP and non-SSP care for OSA.^31,34^ Two studies, however, found that nurse-led OSA care was associated with significantly lower costs per patient^29^ and within-trial costs.^30^

Figure 4 Compliance, Weighted Mean Difference for Hours per Night, Non-sleep Specialist versus Sleep Specialist^a^

^a^ Lower and upper limits represent 95% confidence intervals

PCP = primary care physician

Sleep symptom scores were reported by 5 studies.^29–31,33,34^ All 5 reported ESS scores and all found similar results for groups receiving care from different providers. For the RCTs, the SMD for improvement from baseline was 0.06 (95% CI −0.11, 0.24; I^2^ = 2%) (Figure 5) and the weighted mean difference (WMD) was 0.30 (95% CI −0.50, 1.10). Three studies also reported FOSQ and one reported SASQ scores; 2 reported no significant between group differences in either score.^30,31^ The third study, which used a 3-arm design, found that patients with sleep unit nurse-led follow-up care had lower (ie, worse) FOSQ scores than one of the 2 groups of patients with sleep pulmonologist follow-up.^29^ The difference was small (one point) but statistically significant. There was no difference between the nurse-followed group and the other pulmonologist group. AHI was reported by one study, which found that residual AHI on CPAP was significantly lower in patients referred for PSG by non-SSPs than in patients referred by SSPs (P<.001).^35^

Figure 5 Epworth Sleepiness Scores, Standardized Mean Differences for Mean Change from Baseline, Non-sleep Specialist versus Sleep Specialist^a^

^a^ Lower and upper limits represent 95% confidence intervals

PCP = primary care physician

One RCT reported dryness (54%), nasal congestion (40%), and abrasions (25%) but did not provide separate data for the 2 study groups.^29^ An observational study reported no significant differences between groups in the percentages of patients who discontinued therapy although reasons for discontinuing were not reported.^33^ In one study, changes in weight loss and blood pressure were similar with primary care management of OSA as compared to SSP care.^31^ Time to initiation of therapy was reported in 2 studies. One found that significantly fewer patients in the primary care group received CPAP within one month of PSG when compared to patients in the SSP group (P = .012).^36^ The other reported that while groups were similar in satisfaction with time waiting (P = .71), patients receiving nurse-led care were more satisfied with their impression of wait time (P = .004).^30^ No studies reported oxygen saturation, HbA1c, or BMI.

## KEY QUESTION #1A Do effectiveness/harms/resource utilization vary by patient characteristics: a. Unexplained daytime sleepiness/fatigue b. AHI severity c. Other risk factors or coexisting conditions associated with OSA (eg, obesity, neck circumference, treatment-resistant hypertension, diabetes, age, sex, race) d. Symptoms (eg, nocturia, loss of libido, snoring, witnessed sleep “apnea”)?

Few studies provided information to address KQ1A.

### A Unexplained Daytime Sleepiness/Fatigue

Of the studies eligible for KQ1, 2 required patients to have at least mild daytime sleepiness (ESS ≥8)^30,31^ and one required an ESS ≥12.^29^ Another study did not report ESS but noted that 68% of patients reported excessive sleepiness at baseline.^36^ No study reported results for subgroups of patients based on daytime sleepiness. In addition, with sporadic outcome reporting, it was not possible to determine whether results were different in studies that required a measure of sleepiness for study inclusion versus those that did not.

### B AHI Severity

Four studies reported baseline AHI. Values ranged from 21/hour^33^ to 68/hour.^30^ In one of the studies, 55% were diagnosed with severe OSA (AHI ≥30/hour).^35^ Similar to the finding for daytime sleepiness, no study reported results for subgroups of patients based on AHI and it was not possible to determine whether results were different in the studies with higher baseline AHI values.

### C Other Risk Factors or Coexisting Conditions Associated with OSA

Each of the 7 studies with newly evaluated/diagnosed patients reported BMI. Values ranged from 30 kg/m^233^ to 36 kg/m^2^.^35^ One study reported neck circumference (mean of 45.5 cm).^29^ No study reported treatment resistant hypertension but 4 reported percentages of study participants with hypertension ranging from 38%^32^ to 58%.^35^ Three reported percentages of participants with diabetes (14% to 26%).^32,35,36^ As noted previously, mean age in the 8 studies was 52 years with little variation across studies (range 48 to 59 years). The mean percentage of male study participants was 67% but values ranged from 47% to 85%. No study reported results for subgroups of patients based on obesity, neck circumference, hypertension, diabetes, age, or gender.

One study from the US (Chicago) reported race with 54% African American and 46% non-African American.^35^ In a model adjusted for age, sex, BMI, Medicaid insurance, AHI, ESS, Center for Epidemiologic Studies Depression Scale, and education level, African Americans used CPAP an average of 56 minutes/day less than non-African Americans (P = .002) It was not reported whether there was an interaction with physician specialty.

### D Symptoms

Four studies addressed snoring. In 2 studies, snoring was an inclusion criterion with “habitual snoring” being a high-risk feature in one study^33^ and history of snoring “most” or “every” night being a factor in patient referral in another study.^30^ Two studies reported the percentage of patients with snoring at baseline: 100%^29^ and 83%.^36^ None of the studies reported results for subgroups of patients based on snoring as an inclusion criterion or a baseline factor.

### Strength of Evidence for Key Question 1 (Table 4, Appendix D)

Table 4 Strength of Evidence for Outcomes, Key Question 1

Comparison | Outcome of Interest | Strength of Evidence | Direction | Findings
KQ1: Sleep physician care compared to management by primary care, sleep- specialist nurses or other non-sleep physicians | Access to care | Insufficient | | We found no evidence for this outcome.
KQ1: Sleep physician care compared to management by primary care, sleep- specialist nurses or other non-sleep physicians | Epworth Sleepiness Scale (ESS) | Moderate | Similar | Based on 4 RCTs (n = 568) with aggregate moderate risk of bias, we found improvement from baseline in ESS scores was similar for patients being managed by primary care/sleep-specialist nurses compared to SSPs (SMD = 0.06 [95% CI −0.11, 0.24]). One observational study also found ESS scores were similar between groups.
KQ1: Sleep physician care compared to management by primary care, sleep- specialist nurses or other non-sleep physicians | Quality of life | Moderate | Similar | Based on 3 RCTs (n = 524) with aggregate moderate risk of bias, we found quality of life measures were similar for patients being managed by primary care/sleep-specialist nurses compared to SSPs. SMDs for SF-36 Vitality and Mental Health scores were −0.04 [95% CI −0.22, 0.15]) and −0.04 [95% CI −0.22, 0.14], respectively.
KQ1: Sleep physician care compared to management by primary care, sleep- specialist nurses or other non-sleep physicians | Compliance, hours per night | Moderate | Similar | Based on 4 RCTs (n = 568) with aggregate moderate risk of bias, we found compliance was similar for patients being managed by primary care/sleep-specialist nurses compared to SSPs (WMD = −0.25 [95% CI −0.72, 0.22]). One observational cohort study also found compliance was similar between groups but one study based on retrospective chart review reported compliance was greater in the SSP group compared to the non-sleep specialist group.
KQ1: Sleep physician care compared to management by primary care, sleep- specialist nurses or other non-sleep physicians | Adverse events | Insufficient | | Based on the findings of one RCT (n = 65) that did not report adverse events by treatment arm, the evidence is insufficient to draw conclusions.

APAP = Auto-adjusted (autoregulated) continuous positive airway pressure; CPAP = continuous positive airway pressure; RCT = randomized controlled trial; SAQLI = Sleep Apnea Quality of Life Index; SF-36 = Short Form-36; SMD = standardized mean difference; WMD = weighted mean difference.

a Strength of Evidence Definitions;^28^ See Appendix D for more details

• High: Very confident that estimate of effect lies close to true effect. Few or no deficiencies in body of evidence, findings believed to be stable.

• Moderate: Moderately confident that estimate of effect lies close to true effect. Some deficiencies in body of evidence; findings likely to be stable, but some doubt.

• Low: Limited confidence that estimate of effect lies close to true effect; major or numerous deficiencies in body of evidence. Additional evidence necessary before concluding that findings are stable or that estimate of effect is close to true effect.

• Insufficient: No evidence, unable to estimate an effect, or no confidence in estimate of effect. No evidence is available or the body of evidence precludes judgment.

There was insufficient evidence for access to care and adverse events. Strength of evidence for quality of life, ESS, and CPAP compliance (hours of use per night) was rated as moderate. Quality of life, ESS, and compliance were similar for patients managed by practitioners who are not sleep physicians compared to patients managed by SSPs.

## KEY QUESTION #2 For adults with suspected OSA, what are the effectiveness/harms/resource utilization of electronic consultation versus interactive (eg, in-person, telephone) consultation?

## Key Question #2A Do effectiveness/harms/resource utilization vary by patient characteristics: a. Unexplained daytime sleepiness/fatigue b. AHI severity c. Other risk factors or coexisting conditions associated with OSA (eg, obesity, neck circumference, treatment-resistant hypertension, diabetes, age, sex, race) d. Symptoms (eg, nocturia, loss of libido, snoring, witnessed sleep “apnea”)?

We found no studies that addressed KQ2 or KQ2a.

## KEY QUESTION #3 For adults diagnosed with OSA, what are the effectiveness/harms/resource utilization (including cost avoidance) of using in-home autotitrating continuous positive airway pressure (APAP) technology compared to standard continuous positive airway pressure (CPAP) titrated by in-lab PSG?

### Summary of Findings for Key Question 3

#### Titration

- Few studies compared clinical (ie, patient-centered) outcomes between in-lab CPAP titration and at-home APAP titration. In limited reporting, study groups were generally similar on measures of quality of life (moderate strength of evidence) and cognitive symptoms. Some differences were noted for resource utilization and patient preference.
- Intermediate outcomes (ie, sleep measures, blood pressure, adverse events, and compliance/adherence) were more commonly reported and generally similar. Strength of evidence for ESS was moderate and strength of evidence for compliance was low. Strength of evidence for adverse events was insufficient.

#### Treatment

- Twenty-three studies compared treatment with CPAP to treatment with APAP. The studies enrolled patients with a broad range of baseline AHI values.
- Few studies reported clinical (ie, patient-centered) outcomes other than quality of life and patient preference for one treatment approach over another. Quality of life, assessed with the SF-36, was generally similar between the CPAP and APAP groups (moderate strength of evidence). Patient preference was also generally similar or favored APAP in studies reporting statistical significance. Strength of evidence was insufficient for access to care.
- Intermediate outcomes including post-treatment ESS scores were frequently reported and generally similar for the 2 treatment approaches (moderate strength of evidence). Adverse events were mild and similar for APAP and CPAP (low strength of evidence).
- Compliance, reported as either hours per night or the proportion of nights the device was used, was also similar for the CPAP and APAP treatment groups (moderate strength of evidence).

### Titration

#### Overview of Studies – Table 5; Appendix C, Table 7

Table 5 Key Question 3, Titration: Study Characteristics

Characteristic | Weighted Mean (range) Unless otherwise noted | Number of studies reporting
Total number enrolled/randomized | 622 (68–245) | 4
Randomized controlled trials, total n | 482 (68–245) | 3
Other, total n | 140 | 1
Age of subjects (years) | 50 (46–54) | 4
Percent Male | 76 (67–88) | 4
Baseline BMI (kg/m^2^) | 33 (29.3–38.5) | 4
Baseline ESS | 14.7 (14.0–15.6) | 3
Baseline AHI (events/hour) | 43 (21.2–62.3) | 3
Percent with hypertension (%)^*^ | 45 (32–56) | 2
Location - North America, total n | 208 (68–140) | 2
Location - Europe, total n | 213 | 1
Location - Australia/New Zealand, total n | 169 | 1

* as defined by study

Four studies compared titration of positive airway pressure using in-lab CPAP versus at-home APAP to determine a final long-term CPAP pressure setting.^33,37–39^ Three were RCTs conducted in Canada,^39^ Australia,^38^ and Spain.^37^ The fourth study, a cohort study, was done in the US.^33^ Follow-up periods ranged from 4 to 12 weeks. Sample sizes ranged from 68^39^ to 245^37^ at baseline but at least 10% of the sample was not included in the final analysis of each study. Each of the studies was rated medium risk of bias.

In 3 of the studies, all of the study participants had a diagnostic PSG.^33,37,38^ In the cohort study, those diagnosed with OSA (defined as an AHI > 5/hour with compatible symptoms) and eligible for the home sleep study program (having at least 2 high-risk features such as habitual snoring and daytime fatigue) were included.^33^ The RCT from Australia required patients to have symptomatic OSA, defined as ESS ≥8 and AHI ≥15/hour.^38^ The RCT from Spain also required patients to have symptomatic OSA, defined as ESS ≥12 and AHI ≥30/hour.^37^

In the remaining RCT, patients with clinical suspicion of moderate to severe OSA were evaluated using a diagnostic algorithm. Patients with ESS ≥10, Sleep Apnea Clinical Score (SACS) ≥15, and RDI ≥15/hour (respiratory disturbance index, a measure similar to AHI) were eligible for the study.^39^ The group assigned to in-lab CPAP titration underwent PSG to evaluate the performance of the diagnostic algorithm and 34 of 36 patients had an AHI ≥15/hour (probability of moderate to severe OSA 0.94 (95% CI 0.81, 0.99)).

Baseline ESS scores were similar in all 4 studies, ranging from 14.0 to 15.5 with the highest score in the study requiring an AHI ≥30/hour.^37^ Baseline AHI values ranged from 21/hour^33^ to 62/hour.^37^

#### Clinical Outcomes - Table 6, Appendix C Tables 8–9

Table 6 Clinical Outcomes Comparing APAP to CPAP, Titration Studies

Author, Year Enrolled/Randomized (n) Study Design | All-cause Mortality | Normalization of AHI | MID | | Quality of Life | | Patient Satisfaction | | Resource Utilization | | | | Access to Care | Libido | % Achieving Target | | | | Cognitive Symptoms | Patient Preference | Other
Author, Year Enrolled/Randomized (n) Study Design | All-cause Mortality | Normalization of AHI | ESS | Urinary Symptom Scores | SF-36 | SAQLI | VAS | VSQ-9 | Hospitalization | Treatment | Provider Contact | Referrals | Access to Care | Libido | Weight Loss | BMI | Blood Pressure | HbA1c | Cognitive Symptoms | Patient Preference | Other
Lettieri 2011^33^ (n = 140) Obs. Cohort
McArdle 2010^38^ (n = 169) RCT | | | | | ↔ | | | | | ↕ | ↓ | | | | | | | | ↔
Mulgrew 2007^39^ (n = 68) RCT | | | | | | ↔ | | | | | | | | | | | | | | X
Masa 2004^37^ (n = 245) RCT | | | | | ↕
Total 4 studies (n = 622) | 0 | 0 | 0 | 0 | 1↔ 1↕ | 1↔ | 0 | 0 | 0 | 1↕ | 1↓ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1↔ | 1X | 0

MID = minimally important difference; AHI = apnea-hypopnea index; ESS = Epworth Sleepiness Scale; BMI = body mass index; SF-36 = 36 item short form survey; SAQLI = Sleep Apnea Quality of Life Index; VAS = visual analogue scale; VSQ-9 = Visit-Specific Satisfaction Instrument; HbA1c = hemoglobin A1c; Obs = observational

↑ = significantly better with APAP than CPAP, ↔ = non-significant difference between APAP and CPAP, ↓ = significantly better with CPAP than APAP, ↕ = mixed results comparing APAP and CPAP, X = between group significance not reported; number before symbol indicates number of studies

None of the studies reported all-cause mortality; minimally important differences in AHI, ESS, or urinary symptom scores; patient satisfaction; hospitalizations; access to care; libido; or percent achieving targets for weight loss, BMI, blood pressure, or HbA1c. Quality of life measures were most commonly reported including SF-36 (2 RCTs) and the Sleep Apnea Quality of Life (SAQLI) (1 RCT).

In the study from Spain, SF-36 scores were reported as change from baseline. There was a significant (P<.01) improvement from baseline for both groups in the physical score while the mental score improved from baseline only for the in-lab CPAP titration group.^37^ The Australian study found CPAP and APAP titration resulted in similar scores at the 4-week follow-up for both the physical and mental components of the SF-36.^38^ Standard mean difference for the change from baseline in the mental and physical health components of the SF-36 are depicted in Figure 6.

Figure 6 SF 36 Scores, Standardized Mean Differences in Mean Change from Baseline, Titration Studies^a^

^a^ Lower and upper limits represent 95% confidence intervals

One RCT reported several resource utilization outcomes.^38^ During the 4-week study period, there were more humidifiers issued to the home APAP group but fewer chin straps. Technologist staff time for education was similar in the 2 groups as was the time required for follow-up clinics and telephone calls. Technologist time was significantly higher for the home APAP group compared to the in-lab titration group on titration morning. Technologist time for the home APAP group included time needed to download data from the home device. Physician time for titration study reporting was significantly higher in the in-lab titration group compared to the home APAP group as the physician analyzed the manual titration results to determine the fixed pressure for CPAP therapy. Physician time for follow-up clinics was similar.

The same study reported cognitive outcomes.^38^ Baseline and 4-week scores on the Trails A and Trails B cognitive function tests were similar in the in-lab CPAP and home APAP groups.

One study reported patient preference.^39^ Sixty-two percent in the in-lab study group would have preferred home management while 6% of the home groups would have preferred in-lab management.

#### Intermediate Outcomes – Table 7; Appendix C, Tables 10–12

Table 7 Intermediate Outcomes Comparing APAP to CPAP, Titration Studies

Author, Year Enrolled/Randomized (n) Study Design | AHI | Oxygen Saturation | | | | Sleep Symptom Scores | | | | | | | | Weight Loss | BMI | Blood Pressure | HbA1c | Adverse Events | Costs | Compliance/Adherence
Author, Year Enrolled/Randomized (n) Study Design | AHI | Mean | Time <90% | ODI | Minimum | ESS | FOSQ | SASQ | Arousals | Total Sleep Time | PSQI | Snoring | Other | Weight Loss | BMI | Blood Pressure | HbA1c | Adverse Events | Costs | Hrs/night | Proportion of Nights | Regular Use^a^ | Other
Lettieri, 2011^33^ (n = 140) Obs. Cohort | | | | | | ↔ | | | | | | | | | | | | ↔ | | ↔ | ↔ | ↔
McArdle, 2010^38^ (n = 169) RCT | ↔ | ↔ | ↔ | | | ↔ | | | ↔ | ↔ | | | | | | ↔ | | | X | ↔ | | | ↔^b^
Mulgrew, 2007^39^ (n = 68) RCT | ↔ | | | | | ↔ | | | | | | | | | | | | | | ↑
Masa, 2004^37^ (n = 245) RCT | ↔ | | ↔ | | | ↔ | ↔ | | ↔ | | | | | | | | | ↔ | | ↔
Total 4 studies (n = 622) | 3↔ | 1↔ | 2↔ | 0 | 0 | 4↔ | 1↔ | 0 | 2↔ | 1↔ | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 2 ↔ | 2X | 1↑ 3↔ | 1↔ | 1↔ | 1↔

a as defined by study

b percentage of patients continuing to use CPAP

AHI = apnea-hypopnea index; ODI = oxygen desaturation index; ESS = Epworth sleepiness scale; FOSQ = functional outcomes of sleep questionnaire; PSQI = Pittsburgh sleep quality index; BMI = body mass index

↑ = significantly better with APAP than CPAP, ↔ = non-significant difference between APAP and CPAP, ↓ = significantly better with CPAP than APAP, ↕ = mixed results comparing APAP and CPAP, X = between group significance not reported; number before symbol indicates number of studies

Changes in sleep measures were commonly reported with the in-lab CPAP titration and home APAP titration groups, and found to be similar at follow-up. Three RCTs reported AHI values on PAP were similar at 4 weeks^38^ and 12 weeks.^37,39^ Two RCTs reported oxygen saturation outcomes finding the groups to be similar at 4 weeks^38^ and 12 weeks.^37^ All 4 studies reported ESS scores and found the titration groups were similar at follow-up. For the 2 RCTs reporting mean ESS scores, the SMD in change in ESS scores from baseline was 0.00 (95% CI −0.22, 0.21; I^2^ = 0%) (Figure 7) and the WMD was −0.01 (95% CI −1.11, 1.10).^37,38^

Figure 7 Epworth Sleep Scores, Standardized Mean Difference for Mean Change from Baseline, Titration Studies^a^

^a^ Lower and upper limits represent 95% confidence intervals

Other sleep symptom measures included the FOSQ,^37^ Arousal Index,^37,38^ and total sleep time;^38^ these were also similar at follow-up for the in-lab CPAP and home APAP groups.

One study reported blood pressure.^38^ At 4 weeks follow-up, the in-lab CPAP and home APAP groups had similar systolic and diastolic blood pressures. No studies reported on weight loss, BMI, or HbA1c.

The cohort study reported on discontinuation of therapy during the 4–6 week follow-up and found similar discontinuation rates – 8.6% of the in-lab CPAP group and 10% of the home APAP groups discontinued treatment.^33^ The RCT from Spain reported “secondary effects” (eg, oral dryness, mask intolerance, noise, headache, claustrophobia, smothering sensations, bed partner intolerance) noting that there were no important differences between the in-lab CPAP and home APAP groups.^37^

One study reported staff costs per patient and capital equipment and consumable costs per patient. Both were higher for the in-lab CPAP group but the statistical significance of the findings was not reported.^38^

Each of the studies reported on PAP use (ie, hours per night). Three studies reported that the in-lab CPAP and home APAP groups were similar^33,37,38^ while one reported significantly (P = .02) more hours per night (median 6.0 vs 5.4) in the home APAP group.^39^ Mean differences from the RCTs are presented in Figure 8. The pooled mean difference was 0.02 (95% CI −0.41, 0.45).

Figure 8 Compliance, Weighted Mean Difference for Hours per Night, Titration Studies^a^

^a^ Lower and upper limits represent 95% confidence intervals

Other reported adherence/compliance measures were similar for the 2 groups including percentage of nights used,^33^ use of device for more than 4 hours per night for more than 70% of nights,^33^ and percentage of patients continuing to use device at 4 week follow-up.^38^

One study reclassified participants into “adherent” and “non-adherent” groups based on use of the device for more than 4 hours per night for more than 70% of nights.^33^ Age, gender, BMI, AHI, and baseline sleepiness did not influence use of the PAP device.

### Treatment

#### Overview of Studies –Table 8; Appendix C, Table 7

Table 8 Key Question 3, Treatment: Study Characteristics

Characteristic | Weighted Mean (range) Unless otherwise noted | Number of studies reporting
Total number enrolled/randomized | 1260 (10–200) | 23
Randomized controlled trials, total n | 486 (21–109) | 7
Crossover studies, total n | 600 (10–200) | 15
Other, total n | 174 | 1
Age of subjects (years) | 53 (45–57) | 23
Percent Male | 87 (75–100) | 22
Baseline BMI | 33 (29.3–49.9) | 22
Baseline ESS | 11.8 (6.4–17.4) | 20
Baseline AHI (events/hour) | 44 (14.7–75.8) | 19
Percent with hypertension (%)^*^ | 28 (20–55) | 2
Location - North America, total n | 119 (10–109) | 2
Location - Europe, total n | 1,018 (20–200) | 17
Location - Australia/New Zealand, total n | 77 (12–55) | 3
Location - Multi-national, total n | 46 | 1

* as defined by study

We included 23 studies (with 1,260 patients) comparing CPAP to APAP for treatment of OSA.^40–62^ Most of the studies included an in-lab CPAP titration study, but 4 of the 23 studies put patients on APAP without a titration study.^43,56,59,62^ In 2 of those 4 studies, the CPAP fixed pressure was based on a 1-week^62^ or 2-week^59^ adaptation period of APAP (rather than an in-lab titration study). Three studies were rated low risk of bias^52,54,61^ and the remaining studies medium risk of bias.

There were 22 RCTs (15 of which used a crossover design) and one retrospective cohort study.^58^. One study was conducted in the US with a VA population.^43^ Of the remaining studies, one was conducted in Canada, 3 in Australia or New Zealand, and 17 in Europe.

Individual study sample sizes ranged from 10^47^ to 200.^61^ Among the non-crossover RCTs, treatment periods ranged from one^43^ to 6^50,62^ months. In the crossover studies, treatment phases ranged from 6 nights^40^ to 2 months/8 weeks.^42,45,46,51,53,60^ Several of the crossover studies reported either a washout period between study arms or exclusion of data collected during an initial period of use following a change to a different protocol.

Patient inclusion criteria varied in the 23 studies. All but 3 studies enrolled patients based on AHI. Minimum AHIs for enrollment were 5/hour,^46,51,58^ 10/hour,^42,45,54,57,59^ 15/hour,^40,41,47,49,61^ 20/hour,^53,55,60^ and 30/hour.^48,50,56^ One study included patients with a home sleep test AHI above 10/hour or a laboratory PSG AHI above 20/hour.^44^ Three studies did not specify a minimum AHI. In one, patients were referred for PSG based on the Berlin Questionnaire.^43^ Another included patients based on excessive daytime sleepiness and an ESS above 9.^62^ The third study enrolled patients who were already being treated with CPAP.^52^ Of the studies specifying an AHI, 11 also required clinical symptoms: sleepiness in 4^44,54,59,61^ and daytime symptoms in 2.^41,58^

Baseline values for AHI ranged from 15/hour^51^ (a study that required participants to have AHI values between 5/hour to 30/hour) to 76/hour^40^ (a study that required participants to have an AHI of 15/hour or higher with morbid obesity). The baseline value was below 20/hour in one study, between 31 and 40/hour in 3 studies, between 41 and 50/hour in 8 studies, and 51/hour or higher in 7 studies. No studies had baseline values between 21 and 30/hour; 4 did not report baseline AHI.

Baseline ESS scores ranged from 6.4^58^ to 17.4^40^ in 21 studies. Two studies did not report baseline ESS scores.

#### Clinical Outcomes – Table 9; Appendix C, Table 8–9

Table 9 Clinical Outcomes Comparing APAP to CPAP, Treatment Studies

Author, Year Enrolled/Randomized (n) Study Design | All-cause Mortality | Normalization of AHI | MID | | Quality of Life | | Patient Satisfaction | | Resource Utilization | | Access to Care | Diagnosis of Cognitive Impairment | Patient Preference | Other
Author, Year Enrolled/Randomized (n) Study Design | All-cause Mortality | Normalization of AHI | ESS | Urinary Symptom Scores | SF-36 | SAQLI | VAS | VSQ-9 | Hospitalization | Provider Contact | Access to Care | Diagnosis of Cognitive Impairment | Patient Preference | Other
Bakker 2011^40^ (n = 12) crossover | | | | | | | | | | | | | X
Drummond 2010^43^ (n = 109) RCT | X | | | | | | | | X
Vennelle 2010^61^ (n = 200) crossover | X | | | | ↔ | | | | | ↔ | | | ↔
Damjanovic 2009^41^ (n = 100) RCT
Galetke 2008^45^ (n = 20) crossover | | | | | | | | | | | | | ↑
Fietze 2007^44^ (n = 21) RCT | | | | | ↔
Meurice 2007^50^ (n = 83) RCT | | | | | X
Nolan 2007^51^ (n = 29) crossover | | | | | | | | | | | | | X
Patruno 2007^55^ (n = 40) RCT
Richard 2007^58^ (n = 174) retro cohort | X | | | | | | ↔
Nolan 2006^52^ (n = 27) crossover | | | | | ↔ | | | | | | | | X
Nussbaumer 2006^54^ (n = 34) crossover | | | | | ↔ | | | | | | | | ↑
West 2006^62^ (n = 98) RCT | | | | | ↔ | ↔ | | | | X
Hukins 2004^46^ (n = 55) crossover | | | | | ↔ | | ↔ | | | ↔
Hussain 2004^47^ (n = 10) crossover | | | | | | | | | | | | | ↔
Marrone 2004^48^ (n = 22) crossover | | | | | | | | | | | | | X
Noseda 2004^53^ (n = 27) crossover | | | | | | | | | | | | | X
Massie 2003^49^ (n = 46) crossover | | | | | ↑
Planes 2003^56^ (n = 35) RCT | | | | | | | | | | | | | | ↔^a^
Senn 2003^59^ (n = 31) crossover | | | ↔ | | ↔ | | | | | | | | X
Randerath 2001^57^ (n = 52) crossover | | | | | | | | | | | | | ↑
D’Ortho 2000^42^ (n = 25) crossover | | | | | | | | | | | | | X
Teschler 2000^60^ (n = 10) crossover
Total 23 studies (n = 1,260) | 3X | 0 | 1↔ | 0 | 1↑ 7↔ 1X | 1↔ | 2↔ | 0 | 1X | 2↔ 1X | 0 | 0 | 3↑ 2↔ 7X | 1↔

a tolerance

↑ = significantly better with APAP than CPAP, ↔ = non-significant difference between APAP and CPAP, ↓ = significantly better with CPAP than APAP, ↕ = mixed results comparing APAP and CPAP, X = between group significance not reported

The most frequently reported clinical outcomes were patient preference (12 studies) and quality of life assessed with the SF-36 (9 studies). In 7 of the 12 studies reporting preference, patients preferred APAP over CPAP. The difference was reported to be statistically significant in 3 studies.^45,54,57^ Four studies did not report statistical significance.^40,42,48,53^ The percentage of patients expressing a preference for APAP or CPAP was similar in 5 studies with 2 reporting the statistical significance for the comparison.^47,61^ No study reported a significantly higher patient preference for CPAP. In 4 studies reporting, between 10% and 72% of patients did not express a preference.^48,51,59,61^

Seven of the 9 studies reporting SF-36 quality of life found the APAP and CPAP groups to be similar post-intervention.^44,46,52,54,59,61,62^ One study reported a significantly higher mental health composite score in the APAP group.^49^ The remaining study did not report statistical significance for between group comparisons.^50^ One study also reported groups were similar for the SAQLI.^62^

All-cause mortality was reported in 3 studies with no or few events.^43,58,61^ One study reported that a minimally important difference in ESS scores was achieved in both study groups.^59^ The minimally important difference was 2 points. Patient satisfaction (2 studies) was similar for the APAP and CPAP groups.^46,58^ Four studies reported measures of resource utilization including hospitalization for chest pain,^43^ seeking help from the sleep center,^61^ extra calls or visits with sleep nurses,^62^ or unplanned contacts and duration of unplanned contacts.^46^ finding the groups were similar or not reporting statistical significance.

No study reported minimally important differences in urinary symptom scores, access to care, or diagnosis of cognitive impairment.

#### Intermediate Outcomes – Table 10; Appendix C, Tables 10–12

Table 10 Intermediate Outcomes Comparing APAP to CPAP, Treatment Studies

Author, Year Enrolled/Randomized (n) Study Design | AHI | Oxygen Saturation | | | | Sleep Symptom Scores | | | | | | | | Weight Loss | BMI | Blood Pressure | HbA1c | Time to Initiation of Therapy | Adverse Events | Costs | Compliance/Adherence
Author, Year Enrolled/Randomized (n) Study Design | AHI | Mean | Time <90% | ODI | Minimum | ESS | FOSQ | SASQ | Arousals | Total Sleep Time | PSQI | Snoring | Other | Weight Loss | BMI | Blood Pressure | HbA1c | Time to Initiation of Therapy | Adverse Events | Costs | Hrs/night | Proportion of | Regular Use | Other
Bakker 2011^40^ (n = 12) crossover | ↔ | ↓ | ↔ | ↔ | | ↔ | | | | ↔ | | | | | | | | | | | ↔
Drummond 2010^43^ (n = 109) RCT | | | | | | ↔ | ↔
Vennelle 2010^61^ (n = 200) crossover | ↔ | | | | | ↑ | | | | | | | | | | | | | | | ↑
Damjanovic 2009^41^ (n = 100) RCT | ↔ | | | ↔ | | ↔ | | | ↔ | | | | | | X | | | | | | ↔ | ↔ | | ↔^a^
Galetke 2008^45^ (n = 20) crossover | ↔ | | | | ↔ | ↔ | | | ↔ | | | ↔ | | | | | | | | | ↔
Fietze 2007^44^ (n = 21) RCT | ↔ | | | | | ↔ | | | | | | | | | | | | | | | ↔ | ↔
Meurice 2007^50^ (n = 83) RCT | X | ↔ | ↔ | | | ↔ | | | | X | | | | | | | | | | | ↔
Nolan 2007^51^ (n = 29) crossover | ↔ | ↔ | | | | ↔ | | | ↑ | ↔ | | ↔ | | X | | X | | | X | | ↔ | ↔
Patruno 2007^55^ (n = 40) RCT | ↓ | ↔ | | ↓ | | | | | | | | | | | X | X | | | | | ↔
Richard 2007^58^ (n = 174) retro cohort | | | | | | | | | | | | | | | | | | | | | ↔ | ↔ | X
Nolan 2006^52^ (n = 27) crossover | | | | | | ↔ | | | | | | | | | | | | | X | | ↕ | ↕
Nussbaumer 2006^54^ (n = 34) crossover | ↔ | | | ↔ | | ↔ | | | | | | | | | | | | | ↕ | | ↔ | | ↔
West 2006^62^ (n = 98) RCT | ↔ | | | | | ↔ | | | | | | | ↔^b^ | | ↔ | | | | | | ↔ | ↔
Hukins 2004^46^ (n = 55) crossover | | | | | | ↔ | | | | | | | | | | | | | ↑ | | ↔ | ↔
Hussain 2004^47^ (n = 10) crossover | ↔ | | | ↔ | ↓ | ↔ | | | ↔ | ↔ | | | | | | | | | | | ↔
Marrone 2004^48^ (n = 22) crossover | | | | | | ↔ | | | | | | | | | | | | | | | ↔ | ↔
Noseda 2004^53^ (n = 27) crossover | | | | | | ↑ | | | ↔ | | ↔ | | | | | | | | | | ↔ | ↔
Massie 2003^49^ (n = 46) crossover | ↔ | | | | | ↔ | | | | | | | | | | | | | | | ↑ | ↔
Planes 2003^56^ (n = 35) RCT | ↔ | | ↔ | | | ↔ | | | | | | | | | X | | | ↑ | | ↑ | ↔ | | ↔
Senn 2003^59^ (n = 31) crossover | ↔ | | ↔ | | | ↔ | | | | | | | | | | | | | ↔ | | ↔ | | ↔
Randerath 2001^57^ (n = 52) crossover | X | | | | | X | | | X | X | | X | | | | | | | ↔ | | X | X
D’Ortho 2000^42^ (n = 25) crossover | X | X | | | | X | | | | | | | | | | | | | | | ↔ | | X
Teschler 2000^60^ (n = 10) crossover | X | | | | | | | | | | | | | | | | | | | | ↔ | ↔
Total 23 studies (n = 1,260) | 12↔ 1↓ 4X | 3↔ 1↓ 1X | 4↔ | 4↔ 1↓ | 1↓ 1↔ | 2↑ 16↔ 2X | 1↔ | 0 | 1↑ 4↔ 1X | 3↔ 2X | 1↔ | 2↔ 1X | 1↔ | 1X | 3X | 1↔ 2X | 0 | 1↑ | 1↑ 2↔ 1↕ 2X | 1↑

a hours use/sleep time

b maintenance of wakefulness

↑ = significantly better with APAP than CPAP, ↔ = non-significant difference between APAP and CPAP, ↓ = significantly better with CPAP than APAP, ↕ = mixed results comparing APAP and CPAP, X = between group significance not reported

Intermediate outcomes were more frequently reported. Seventeen studies reported AHI after the treatment periods with 12 finding APAP and CPAP resulted in similar AHI values, one reporting significantly better results with CPAP compared to APAP, and 4 not reporting the significance of the findings. Oxygen saturation measures were reported in 11 studies with most finding APAP and CPAP to be similar.

Sleep symptom scores were also generally similar. The most frequently reported score was the ESS (reported in 20 of the 23 studies). Sixteen studies found the CPAP and APAP groups to be similar, 2 reported the scores were statistically significantly better for the APAP groups, and 2 did not report significance. For the 4 pooled parallel group RCTs, the SMD in improvement from baseline was 0.18 (95% CI −0.06, 0.43; I^2^ = 0%) (Figure 9) and the WMD was 0.85 (95% CI −0.28, 1.99). We included data from the longest follow-up time reported. Findings for other sleep measures including the FOSQ, arousals, total sleep time, PSQI, and snoring were similar between the CPAP and APAP groups.

Figure 9 Epworth Sleepiness Scores, Standardized Mean Difference for Mean Change from Baseline from Parallel Group RCTs, Treatment Studies^a^

^a^ Lower and upper limits represent 95% confidence intervals

Few studies measured changes in weight, BMI, or blood pressure with none reporting a significant difference between groups.^41,51,55,56,62^ One study reported statistically significant decreases in systolic and diastolic blood pressure in the CPAP group but not the APAP group but did not report the significance of the difference between study groups.^55^ No study reported changes in HbA1c.

One study reported time to initiation of therapy follow diagnosis.^56^ Mean time in the APAP group was 12 days compared to 27 days in the CPAP group (P <.01). The difference was attributed to wait time for PSG.

Adverse events were reported in 6 studies. Three found similar frequency of events (dry mouth, blocked/runny nose, skin irritation, nasal irritation, pressure feeling too high, claustrophobia) in the CPAP and APAP groups.^51,57,59^ One found incidence of nasal and throat/mouth symptoms was similar for different APAP devices but did not compare findings to CPAP.^52^ One study reported mixed results (ie, no difference in nasal irritation/obstruction, pressure intolerance, or partner dislike but fewer total side effects [P = .02] in the APAP group).^46^ One reported no side effects requiring alteration of treatment.^54^ In this study, the incidence of nasal and mouth/throat side effects was similar for the CPAP and APAP groups while discomfort with air pressure was significantly higher in the CPAP group.

One study reported costs during a 2-month treatment period.^56^ Hospital costs were significantly lower in the APAP group while telecommunication costs (to transmit data from home to sleep laboratory) were significantly higher (both P <.001). Costs for equipment and home nurse visits were similar for the APAP and CPAP groups. Total cost per patient of the 2-month treatment was lower in the APAP group (€1,264 vs €1,720; P <.01).

Twenty-two of the 23 included studies reported hours per night of use with 19 of 22 reporting the CPAP and APAP groups were similar. Of the remaining 3 studies, 2 noted significantly higher use with APAP^49,61^ and one reported mixed results for different APAP devices.^52^ The differences in means for the 5 non-crossover RCTs are presented in Figure 10. Using data from the longest reported follow-up time, the pooled difference was −0.08 (95% CI −0.55, 0.38; I^2^ = 14%).

Figure 10 Compliance, Weighted Mean Difference for Hours per Night from Parallel Group RCTs, Treatment Studies^a^

^a^ Lower and upper limits represent 95% confidence intervals

The results for proportion of nights used were similar; 10 of 12 studies found the CPAP and APAP groups to be similar, one reported mixed results,^52^ and one did not report statistical significance.^57^ “Regular use,” as defined by the study, was similar in 3 of the 5 studies reporting (with 2 not reporting significance).

## KEY QUESTION #3A Do effectiveness/harms/resource utilization vary by patient characteristics: a. Unexplained daytime sleepiness/fatigue b. AHI severity c. Other risk factors or coexisting conditions associated with OSA (eg, obesity, neck circumference, treatment-resistant hypertension, diabetes, age, sex, race) d. Symptoms (eg, nocturia, loss of libido, snoring, witnessed sleep “apnea”)?

Few studies reported results by patient characteristics.

### A Unexplained Daytime Sleepiness/Fatigue

No study reported results for subgroups of patients based on unexplained daytime sleepiness or fatigue.

### B AHI Severity

One treatment study grouped patients by baseline AHI (< 60/hour or ≥60/hour).^42^ Duration of use (hours/night) of CPAP and APAP was similar in the overall study population. There was significantly longer use of both CPAP and APAP in patients with baseline AHI ≥60/hour compared to those with baseline AHI <60/hour. A second study compared baseline AHI in compliant and non-compliant patients (with compliance defined as at least 4 hours per night for at least 5 days per week). AHI levels did not differ (51/hour for the compliant group, 47/hour for the non-compliant group, P = .40); results were not reported by treatment group.^58^ A third study reported that compliance was similar between CPAP and APAP treatment groups in post-hoc subgroup analyses of patients with differing degrees of OSA severity.^46^

Two treatment studies compared baseline AHI in patients who expressed a preference for CPAP or APAP. One found that baseline AHI was a significant predictor of preference for CPAP or APAP.^48^ Patients who preferred APAP had a higher baseline AHI than patients who preferred CPAP (73.1 vs 60.0/hour, P<.02). The other found AHI values were similar whether patients preferred APAP or CPAP (16.3 vs 14.2/hour, P = .49).^51^

### C Other Risk Factors or Coexisting Conditions Associated with OSA

One treatment study included only morbidly obese (BMI ≥40 kg/m^2^) patients.^40^ Neck circumferences was 46.5 (4.0) cm. CPAP and APAP generally produced similar results; patients were not stratified by BMI.

Two treatment studies evaluated age and compliance. In both studies, older patients tended to be more compliant with therapy but the findings were not statistically significant.^45,58^ One study also reported that baseline BMI and ESS were not associated with compliance.^58^ Neither study reported results by treatment group (CPAP or APAP).

Two studies reported other factors associated with preference for CPAP or APAP. One found that neither age or ESS score at baseline were significant predictors of preference.^48^ Another reported that neither age, BMI, neck circumference, or ESS score were significant predictors.^51^

### D Symptoms

One titration study reported baseline percentages of patients with habitual snoring (88%), observed apneas (61%), and nocturia (27%).^37^ The study did not report results for subgroups of patients based on these characteristics.

### Strength of Evidence for Key Question 3 (Table 4, Appendix D)

#### Titration

For studies comparing in-lab CPAP titration to at-home APAP titration, there was insufficient evidence for the outcomes of access to care and adverse events. Strength of evidence was moderate for quality of life and low for compliance (hours/night) and ESS with similar findings for the 2 study groups.

#### Treatment

Among studies comparing CPAP to APAP for treatment of OSA, there was insufficient evidence for access to care. Strength of evidence was moderate for quality of life, ESS, and compliance (hours/night) and low for adverse events. These outcomes were similar in the 2 treatment groups.

Table 11 Strength of Evidence for Outcomes, Key Question 3

Comparison | Outcome of Interest | Strength of Evidence | Direction | Findings
KQ3: Home APAP technology versus standard in-center manual CPAP titration | Access to care | Insufficient | | We found no evidence for this outcome.
KQ3: Home APAP technology versus standard in-center manual CPAP titration | Epworth Sleepiness Scale (ESS) | Moderate | Similar | Based on 2 RCTs (n = 414) with moderate risk of bias, we found improvement from baseline in ESS scores was similar for patients allocated to home APAP titration compared to patients allocated to in-center CPAP titration (SMD = 0.0 [95% CI −0.22, 0.21]). One moderate risk of bias RCT (n = 68) found median change in EES scores from baseline was also similar between groups (MD 1 [95% CI −1, 4]). One observational cohort study also found ESS scores were similar between groups.
KQ3: Home APAP technology versus standard in-center manual CPAP titration | Quality of life | Moderate | Similar | Based on 2 RCTs (n = 414) with moderate risk of bias, we found quality of life measures were similar for patients allocated to home APAP titration compared to patients allocated to in-center CPAP titration. The SMDs for SF-36 Mental Health and Physical Health scores were 0.08 [95% CI −0.14, 0.29] and −0.21 [95% CI −0.61, 0.20], respectively. Results for the Physical Health scores were imprecise. One moderate risk of bias RCT (n = 68) found median improvement from baseline in the SAQLI was similar between groups (median difference = 0.17 [95% CI −0.6, 0.9])
KQ3: Home APAP technology versus standard in-center manual CPAP titration | Compliance, hours per night | Low | Similar | Based on 2 RCTs (n = 414) with moderate risk of bias, we found compliance was similar for patients allocated to home APAP titration compared to patients allocated to in-center CPAP titration (WMD = 0.02 [95% CI −0.41, 0.45]). One moderate risk of bias RCT (n = 68) found median compliance was better in the APAP group versus the CPAP group (MD −1.1 [95% CI −2.0, −0.2]). One observational cohort study found compliance was similar between groups.
KQ3: Home APAP technology versus standard in-center manual CPAP titration | Adverse events | Insufficient | | Based on the findings of one RCT (n = 245) that reported no “important differences” in adverse events between the home APAP and in-lab CPAP and groups, the evidence is insufficient to draw conclusions.
KQ3: APAP versus CPAP treatment | Access to care | Insufficient | | We found no evidence for this outcome.
KQ3: APAP versus CPAP treatment | Epworth Sleepiness Scale (ESS) | Moderate | Similar | Based on 4 parallel group RCTs (n = 327) with aggregate moderate risk of bias, we found improvement from baseline in ESS scores was similar for patients allocated to APAP treatment compared to patients allocated to CPAP treatment (SMD = 0.18 [95% CI −0.06, 0.43]). Two parallel group trials not pooled (reported as a median or data not shown) also found improvement from baseline in ESS scores similar between groups. Ten crossover RCTs (n = 269) reported similar improvements between groups and 2 (N = 227) reported greater improvement with APAP.
KQ3: APAP versus CPAP treatment | Quality of life | Moderate | Similar | Based on 3 parallel group RCTs (n = 202) with aggregate moderate risk of bias, we found quality of life measures (SF-36, SAQLI) were similar for patients allocated to APAP treatment compared to patients allocated to CPAP treatment (data were not pooled due to variation in reporting of results, ie, reported as medians). Six crossover RCTs (n = 393) also reported no differences in most of the quality of life measures between the treatment groups.
KQ3: APAP versus CPAP treatment | Compliance, hours per night | Moderate | Similar | Based on 5 parallel group RCTs (n = 279) with aggregate moderate risk of bias, we found compliance was similar for patients allocated to APAP treatment compared to patients allocated to CPAP treatment (WMD = −0.08 [95% CI −0.55, 0.38]). One parallel group RCT reporting median compliance, most of the remaining crossover RCTs, and one observational study also found compliance was similar between groups.
KQ3: APAP versus CPAP treatment | Adverse events | Low | Similar | Adverse events were infrequently reported. One parallel group RCT (n = 109) reported adverse events, chest pain in 12% and 9% of APAP and CPAP patients, respectively. Five crossover trials reported adverse events for both APAP and CPAP treatments. One trial (n = 55) reported a higher frequency of total number of events and another trial (n = 34) reported a higher incidence of pressure discomfort with CPAP therapy arm compared with the APAP treatment. There trials (n = 112) reported no differences in adverse events between the treatment groups.

APAP = Auto-adjusted (autoregulated) continuous positive airway pressure; CPAP = continuous positive airway pressure; RCT = randomized controlled trial; SAQLI = Sleep Apnea Quality of Life Index; SF-36 = Short Form-36; SMD = standardized mean difference; WMD = weighted mean difference.

a Strength of Evidence Definitions;^28^ See Appendix D for more details

• High: Very confident that estimate of effect lies close to true effect. Few or no deficiencies in body of evidence, findings believed to be stable.

• Moderate: Moderately confident that estimate of effect lies close to true effect. Some deficiencies in body of evidence; findings likely to be stable, but some doubt.

• Low: Limited confidence that estimate of effect lies close to true effect; major or numerous deficiencies in body of evidence. Additional evidence necessary before concluding that findings are stable or that estimate of effect is close to true effect.

• Insufficient: No evidence, unable to estimate an effect, or no confidence in estimate of effect. No evidence is available or the body of evidence precludes judgment.