# REFERENCES

1 Marin JM, Carrizo SJ, Vicente E, Agusti AG. Long-term cardiovascular outcomes in men with obstructive sleep apnoea-hypopnoea with or without treatment with continuous positive airway pressure: an observational study. Lancet. 2005;365(9464):1046–1053.15781100
2 Peker Y, Hedner J, Norum J, Kraiczi H, Carlson J. Increased incidence of cardiovascular disease in middle-aged men with obstructive sleep apnea: a 7-year follow-up. Am J Respir Crit Care Med. 2002;166(2):159–165.12119227
3 Gottlieb DJ, Yenokyan G, Newman AB, . Prospective study of obstructive sleep apnea and incident coronary heart disease and heart failure: the sleep heart health study. Circulation. 2010;122(4):352–360.20625114
4 Redline S, Yenokyan G, Gottlieb DJ, . Obstructive sleep apnea-hypopnea and incident stroke: the sleep heart health study. Am J Respir Crit Care Med. 2010;182(2):269–277.20339144
5 Yaggi HK, Concato J, Kernan WN, Lichtman JH, Brass LM, Mohsenin V. Obstructive sleep apnea as a risk factor for stroke and death. N Engl J Med. 2005;353(19):2034–2041.16282178
6 Blackwell T, Yaffe K, Laffan A, . Associations of objectively and subjectively measured sleep quality with subsequent cognitive decline in older community-dwelling men: the MrOS sleep study. Sleep. 2014;37(4):655–663.24899757
7 Yaffe K, Laffan AM, Harrison SL, . Sleep-disordered breathing, hypoxia, and risk of mild cognitive impairment and dementia in older women. JAMA. 2011;306(6):613–619.21828324
8 Giles TL, Lasserson TJ, Smith BH, White J, Wright J, Cates CJ. Continuous positive airways pressure for obstructive sleep apnoea in adults. Cochrane Database Syst Rev 2006;(3):CD001106.
9 Tregear S, Reston J, Schoelles K, Phillips B. Continuous positive airway pressure reduces risk of motor vehicle crash among drivers with obstructive sleep apnea: systematic review and meta-analysis. Sleep. Oct 2010;33(10):1373–1380.21061860
10 Peppard PE, Young T, Barnet JH, Palta M, Hagen EW, Hla KM. Increased prvalence of sleep-diordered breathing in adults. Am J Epidemol. 2013;177(9):1006–1014.
11 Frost & Sullivan. Hidden Health Crisis Costing America Billions: Underdiagnosing and Undertreating Obstructive Sleep Apnea Draining Healthcare System. American Academy of Sleep Medicine, 2016, http://www.aasmnet.org/Resources/pdf/sleep-apnea-economic-crisis.pdf. Accessed 22 Sept 2016
12 Balk EM, Moorthy D, Obadan NO, . Diagnosis and Treatment of Obstructive Sleep Apnea in Adults. Comparative Effectiveness Review No. 32. Rockville, MD: AHRQ Publication No. 11-EHC052-EF, 2011.
13 Qaseem A, Dallas P, Owens DK, . Diagnosis of obstructive sleep apnea in adults: a Clinical Practice Guideline from the American College of Physicians. Ann Intern Med. 2014;161:210–220.25089864
14 Qaseem A, Holty J-E, Owens DK, Dallas P, Starkey M, Shekelle P. Management of obstructive sleep apnea in adults: a Clinical Practice Guideline from the American College of Physicians. Ann Intern Med. 2013;159(7):471–483.24061345
15 U.S. Preventive Services Task Force. Draft Recommendation Statement: Obstructive Sleep Apnea in Adults: Screening. 2016. Available from: https://www.uspreventiveservicestaskforce.org/Page/Document/draft-recommendation-statement166/obstructive-sleep-apnea-in-adults-screening. Accessed 21 Sept 2016
16 McEvoy RD, Antic NA, Heeley E, . CPAP for prevention of cardiovascular events in obstructive sleep apnea. New Engl J Med. 2016;375(10):919–931.27571048
17 Hiestand DM, Britz P, Goldman M, Phillips B. Prevalence of symptoms and risk of sleep apnea in the US population: Results from the national sleep foundation sleep in America 2005 poll. Chest. Sep 2006;130(3):780–786.16963675
18 Das SR, Kinsinger LS, Yancy WS, Jr., . Obesity prevalence among veterans at Veterans Affairs medical facilities. Am J Prev Med. Apr 2005;28(3):291–294.15766618
19 Alexander M, Ray MA, Hebert JR, . The National Veteran Sleep Disorder Study: descriptive epidemiology and secular trends, 2000–2010. Sleep. 2016;39(7);1399–1410.27091538
20 NCD Risk Factor Collaboration. Trends in adult body-mass index in 200 countries from 1975 to 2014: a pooled analysis of 1698 population-based measurement studies with 19.2 million participants. Lancet. 2016;387:1377–1396.27115820
21 Phillips B, Gozal D, Malhotra A. What is the future of sleep medicine in the United States? Am J Respir Crit Care Med. 2015;192(8):915–917.26308722
22 Collop NA, Anderson WM, Boehlecke B, . Clinical guidelines for the use of unattended portable monitors in the diagnosis of obstructive sleep apnea in adult patients. Portable Monitoring Task Force of the American Academy of Sleep Medicine. J Clin Sleep Med. 2007;3(7):737–747.18198809
23 Morgenthaler TI, Aurora RN, Brown T, . Practice parameters for the use of autotitrating continuous positive airway pressure devices for titrating pressures and treating adult patients with obstructive sleep apnea syndrome: an update for 2007. An American Academy of Sleep Medicine report. Sleep. Jan 2008;31(1):141–147.18220088
24 Higgins H, Green S. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. The Cochrane Collaboration, 2011.
25 Viswanathan M, Ansarai MT, Berkman ND, . Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Rockville, MD: Agency for Healthcare Research and Quality, 2008.
26 Cohen J. Statistical power analysis for the behavioral sciences, 2nd ed. Hillsdale, NJ: Lawrence Earlbaum Associates; 1988.
27 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557–560.12958120
28 Owens DK, Lohr KN, Atkins D, . AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513–523.19595577
29 Andreu AL, Chiner E, Sancho-Chust JN, . Effect of an ambulatory diagnostic and treatment programme in patients with sleep apnoea. Eur Respir J. 2012;39(2):305–312.21719490
30 Antic NA, Buchan C, Esterman A, . A randomized controlled trial of nurse-led care for symptomatic moderate-severe obstructive sleep apnea. Am J Respir Crit Care Med. 2009;179(6):501–508.19136368
31 Chai-Coetzer CL, Antic NA, Rowland LS, . Primary care vs specialist sleep center management of obstructive sleep apnea and daytime sleepiness and quality of life: a randomized trial. JAMA. 2013;309(10):997–1004.23483174
32 Chamorro N, Sellares J, Millan G, . An integrated model involving sleep units and primary care for the diagnosis of sleep apnoea. Eur Respir J. 2013;42(4):1151–1154.24081767
33 Lettieri CF, Lettieri CJ, Carter K. Does home sleep testing impair continuous positive airway pressure adherence in patients with obstructive sleep apnea? Chest. 2011;139(4):849–854.21292757
34 Palmer S, Selvaraj S, Dunn C, . Annual review of patients with sleep apnea/hypopnea syndrome: a pragmatic randomised trial of nurse home visit versus consultant clinic review. Sleep Med. 2004;5(1):61–65.14725828
35 Pamidi S, Knutson KL, Ghods F, Mokhlesi B. The impact of sleep consultation prior to a diagnostic polysomnogram on continuous positive airway pressure adherence. Chest. 2012;141(1):51–57.21700685
36 Scharf SM, DeMore J, Landau T, Smale P. Comparison of primary-care practitioners and sleep specialists in the treatment of obstructive sleep apnea. Sleep Breath. 2004;8(3):111–124.15389385
37 Masa JF, Jimenez A, Duran J, . Alternative methods of titrating continuous positive airway pressure: a large multicenter study. Am J Respir Crit Care Med. 2004;170(11):1218–1224.15282204
38 McArdle N, Singh B, Murphy M, . Continuous positive airway pressure titration for obstructive sleep apnoea: automatic versus manual titration. Thorax. 2010;65(7):606–611.20627917
39 Mulgrew AT, Fox N, Ayas NT, Ryan CF. Diagnosis and initial management of obstructive sleep apnea without polysomnography: a randomized validation study. Ann Intern Med. 2007;146(3):157–166.17283346
40 Bakker J, Campbell A, Neill A. Randomised controlled trial of auto-adjusting positive airway pressure in morbidly obese patients requiring high therapeutic pressure delivery. J Sleep Res. 2011;20(1 Pt 2):233–240.20545835
41 Damjanovic D, Fluck A, Bremer H, Muller-Quernheim J, Idzko M, Sorichter S. Compliance in sleep apnoea therapy: influence of home care support and pressure mode. Eur Respir J. 2009;33(4):804–811.19129293
42 d’Ortho M, Grillier-Lanoir V, Levy P, . Constant vs automatic continuous positive airway pressure therapy: home evaluation. Chest. 2000;118(4):1010–1017.11035671
43 Drummond F, Doelken P, Ahmed QA, . Empiric auto-titrating CPAP in people with suspected obstructive sleep apnea. J Clin Sleep Med. 2010;6(2):140–145.20411690
44 Fietze I, Glos M, Moebus I, Witt C, Penzel T, Baumann G. Automatic pressure titration with APAP is as effective as manual titration with CPAP in patients with obstructive sleep apnea. Respiration. 2007;74(3):279–286.17337881
45 Galetke W, Anduleit N, Richter K, Stieglitz S, Randerath WJ. Comparison of automatic and continuous positive airway pressure in a night-by-night analysis: a randomized, crossover study. Respiration. 2008;75(2):163–169.17148931
46 Hukins C. Comparative study of autotitrating and fixed-pressure CPAP in the home: a randomized, single-blind crossover trial. Sleep. 2004;27(8):1512–1517.15683142
47 Hussain SF, Love L, Burt H, Fleetham JA. A randomized trial of auto-titrating CPAP and fixed CPAP in the treatment of obstructive sleep apnea-hypopnea. Respir Med 2004;98(4):330–333.15072173
48 Marrone O, Resta O, Salvaggio A, Giliberti T, Stefano A, Insalaco G. Preference for fixed or automatic CPAP in patients with obstructive sleep apnea syndrome. Sleep Med. 2004;5(3):247–251.15165530
49 Massie CA, McArdle N, Hart RW, . Comparison between automatic and fixed positive airway pressure therapy in the home. Am J Respir Crit Care Med. 2003;167(1):20–23.12406840
50 Meurice JC, Cornette A, Philip-Joet F, . Evaluation of autoCPAP devices in home treatment of sleep apnea/hypopnea syndrome. Sleep Med. 2007;8(7–8):695–703.17638595
51 Nolan GM, Doherty LS, Mc Nicholas WT. Auto-adjusting versus fixed positive pressure therapy in mild to moderate obstructive sleep apnoea. Sleep. Feb 2007;30(2):189–194.17326544
52 Nolan GM, Ryan S, O’Connor T M, McNicholas WT. Comparison of three auto-adjusting positive pressure devices in patients with sleep apnoea. Eur Respir J. 2006;28(1):159–164.16571610
53 Noseda A, Kempenaers C, Kerkhofs M, Braun S, Linkowski P, Jann E. Constant vs auto-continuous positive airway pressure in patients with sleep apnea hypopnea syndrome and a high variability in pressure requirement. Chest. 2004;126(1):31–37.15249439
54 Nussbaumer Y, Bloch KE, Genser T, Thurnheer R. Equivalence of autoadjusted and constant continuous positive airway pressure in home treatment of sleep apnea. Chest. 2006;129(3):638–643.16537862
55 Patruno V, Aiolfi S, Costantino G, . Fixed and autoadjusting continuous positive airway pressure treatments are not similar in reducing cardiovascular risk factors in patients with obstructive sleep apnea. Chest. 2007;131(5):1393–1399.17494789
56 Planes C, D’Ortho MP, Foucher A, . Efficacy and cost of home-initiated auto-nCPAP versus conventional nCPAP. Sleep. 2003;26(2):156–160.12683473
57 Randerath WJ, Schraeder O, Galetke W, Feldmeyer F, Ruhle KH. Autoadjusting CPAP therapy based on impedance efficacy, compliance and acceptance. Am J Respir Crit Care Med. Mar 2001;163(3 Pt 1):652–657.11254519
58 Richard W, Venker J, den Herder C, . Acceptance and long-term compliance of nCPAP in obstructive sleep apnea. Eur Arch Otorhinolaryngol. 2007;264(9):1081–1086.17443336
59 Senn O, Brack T, Matthews F, Russi EW, Bloch KE. Randomized short-term trial of two autoCPAP devices versus fixed continuous positive airway pressure for the treatment of sleep apnea. Am J Respir Crit Care Med. 2003;168(12):1506–1511.14525804
60 Teschler H, Wessendorf TE, Farhat AA, Konietzko N, Berthon-Jones M. Two months auto-adjusting versus conventional nCPAP for obstructive sleep apnoea syndrome. Eur Respir J. 2000;15(6):990–995.10885414
61 Vennelle M, White S, Riha RL, Mackay TW, Engleman HM, Douglas NJ. Randomized controlled trial of variable-pressure versus fixed-pressure continuous positive airway pressure (CPAP) treatment for patients with obstructive sleep apnea/hypopnea syndrome (OSAHS). Sleep. 2010;33(2):267–271.20175411
62 West SD, Jones DR, Stradling JR. Comparison of three ways to determine and deliver pressure during nasal CPAP therapy for obstructive sleep apnoea. Thorax. 2006;61(3):226–231.16254055
63 Berry RB, Hill G, Thompson L, McLaurin V. Portable monitoring and autotitration versus polysomnography for the diagnosis and treatment of sleep apnea. Sleep. 2008;31(10):1423–1431.18853940
64 Kuna ST, Gurubhagavatula I, Maislin G, . Noninferiority of functional outcome in ambulatory management of obstructive sleep apnea. Am J Respir Crit Care Med. 2011;183(9):1238–1244.21471093
65 Rosen CL, Auckley D, Benca R, . A multisite randomized trial of portable sleep studies and positive airway pressure autotitration versus laboratory-based polysomnography for the diagnosis and treatment of obstructive sleep apnea: the HomePAP study. Sleep. 2012;35(6):757–767.22654195
66 Chen LM, Kennedy EH, Sales A, Hofer TP. Use of health IT for higher-value critical care. N Engl J Med. 2013;368(7):594–597.23363474