# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Kathleen Sarmiento, MD, MPH, Director of Pulmonary Sleep Medicine, VA San Diego and W. Claibe Yarbrough, MD, National Program Director, Pulmonary/Critical Care/Sleep, on behalf of the Specialty Care Services (10P4E) –Pulmonary/Critical Care/Sleep National Program office. The evidence review examines the effectiveness and harms associated with different care models aimed at increasing access to care for Veterans who have obstructive sleep apnea.

## SEARCH STRATEGY

We searched MEDLINE (Ovid) and CINAHL for articles published from 2000 through May 2016. Our search was limited to studies enrolling adults and published in the English language. The search for KQs 1 and 2 included the MeSH terms sleep apnea syndromes; sleep apnea, obstructive; health personnel; and remote consultation. The search for KQ3 included the MeSH terms home care services, continuous positive airway pressure, and calibration. The full search strategies are presented in Appendix A. We obtained additional articles by hand searching the reference lists of related systematic reviews and relevant studies.

## STUDY SELECTION

All abstracts were independently reviewed by 2 trained investigators and research associates. We included studies of any design that reported results in adults with suspected or diagnosed OSA and were conducted in North America, Europe, Australia, or New Zealand. For KQ1 we excluded studies that did not include a comparison of a supervised practitioner or non-specialist licensed independent practitioner (eg primary care physician, physician’s assistant, nurse, technologist, or respiratory therapist) to a SSP. We excluded studies evaluating the role of dentists or anesthesiologists. We also excluded studies in which the goal of the intervention was not case finding or care for OSA. For KQ2 we excluded studies that did not compare an electronic initial consultation, without patient contact, to an interactive initial consultation. For KQ3 we excluded studies that did not compare the use of APAP to CPAP for titration or treatment of OSA. We also excluded studies that used different diagnostic methods in those treated with APAP versus CPAP. In studies of titration we only included articles in which the APAP was used for titration at home and CPAP was manually titrated in a lab. We also excluded studies if they did not report any of our outcomes of interest (see PICOTS, above). There was no minimum follow-up duration.

Full-text reports of studies identified as potentially eligible were obtained for further review using the inclusion and exclusion criteria described above. Each article was independently reviewed by 2 investigators or research associates. Reasons for excluding a study at full-text review were noted and disagreements were decided by a third reviewer.

## DATA ABSTRACTION

Study characteristics (location, setting, intervention groups, follow-up, aim of study, treatments, inclusion/exclusion criteria, and patient characteristics) as well as intermediate and clinical outcomes (time to initiation of therapy, compliance, AHI, oxygen saturation, sleep symptoms, urinary symptoms, cognitive ability, weight, BMI, libido, blood pressure, HbA1c, harms, overdiagnosis, adverse events, costs, mortality, resource utilization, access to care, quality of life, and patient satisfaction) were extracted onto evidence tables by one investigator or research associate and verified by another.

## RISK OF BIAS ASSESSMENT

Trained research methodologists rated the risk of bias of individual studies as low, moderate, or high risk. One methodologist rated risk of bias and the rating was verified by a second investigator trained in risk of bias assessment. Discrepancies were resolved by discussion. For randomized controlled trials (RCTs), risk of bias ratings were based the following criteria: allocation sequence generation, allocation concealment, blinding, incomplete outcome data, and selective outcome reporting – a modification of the Cochrane approach to determining risk of bias.^24^

For observational studies, risk of bias was rated using criteria suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide: selection bias (use of appropriately comparable control group, design/analysis accounted for important confounding and modifying variables); masking of the outcome assessment (outcome assessor); use of intention-to-treat principles (ie, inclusion of all comparison group participants in outcomes analyses); attrition bias (if overall or differential dropout/loss to follow-up or exclusions a concern, missing data appropriately handled); and selective reporting of pre-specified outcomes.^25^ Observational studies were considered high risk of bias unless all 5 criteria were addressed by the study authors. Studies that addressed all 5 criteria were considered medium or low risk of bias depending on how completely the criteria were addressed.

## DATA SYNTHESIS

We created separate evidence tables for each KQ. We described and qualitatively compared the characteristics and findings of included studies. For KQ1 and KQ3, data were analyzed in Comprehensive MetaAnalysis Version 3 (Biostat, Englewood, New Jersey) using DerSimonian and Laird random effects models to calculate weighted mean differences (WMD) for compliance and standardized mean differences (SMD) for changes from baseline for Epworth Sleepiness Scale (ESS) and quality of life (SF-36) scores with corresponding 95% confidence intervals (CI). SMDs can be interpreted by using Cohen’s definition of small (0.2), medium (0.5), and large (0.8) effect sizes.^26^ Statistical heterogeneity among trials was assessed by using the I^2^ test.^27^ A score of 75% or greater may indicate considerable heterogeneity.

## RATING THE BODY OF EVIDENCE

We assessed strength of evidence using the method described by Owens et al for the following outcomes: access to care, ESS, quality of life, compliance (hours of use per night), and adverse events. Strength of evidence for an outcome was rated as high, moderate, low, or insufficient. This rating was based on precision (degree of certainty in the estimate of effect), consistency (direction of effect across included studies), directness (whether evidence links intervention directly to health outcomes), and risk of bias of the individual studies (as described above).^28^ One methodologist rated strength of evidence and the rating was verified by a second. Discrepancies were resolved by discussion.

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer comments and our responses are presented in Appendix B and the report was modified as needed.