# INTRODUCTION

Obstructive sleep apnea (OSA) is a chronic condition that results from repeated closure of the upper airway during sleep resulting in reduced airflow (hypopnea) or complete airflow cessation (apnea) leading to cyclic sleep disruption. Subsequently, patients with OSA frequently experience excessive daytime sleepiness and decreased quality of life. However, not all individuals have excessive daytime sleepiness and symptoms are not required to make a diagnosis or obtain treatment. OSA has also been associated with a higher risk of myocardial infarction,^1,2^ heart failure,^3^ stroke,^4,5^ and cognitive decline.^6,7^ The severity of OSA can be categorized as mild, moderate, or severe based on the number of apnea and hypopnea events per hour (known as the apnea-hypopnea index [AHI]). An AHI of 5/hour to fewer than 15/hour is considered mild, 15/hour to fewer than 30/hour is considered moderate, and 30/hour or greater is considered severe. Continuous positive airway pressure (CPAP) effectively reduces AHI in most patients with OSA, improves blood pressure, and particularly in those with symptoms of excessive daytime sleepiness, improves quality of life and sleep symptoms.^8^ CPAP use is also associated with a reduced risk of motor vehicle accidents.^9^

The estimated prevalence of mild to severe OSA based on AHI thresholds (AHI ≥5/hour) in the United States (2007–2010 data) among 30- to 70-year-olds regardless of symptom status is 34% for men and 17% for women.^10^ The corresponding values for moderate to severe OSA (AHI ≥ 15/hour) are 13% for men and 6% for women. The prevalence of 30–70 year olds with AHI ≥ 5/hour and daytime sleepiness (Epworth Sleepiness Scale score > 10) is 14% for men and 5% for women. Current prevalence of abnormal AHI may be higher due to rising rates of obesity and increased testing for OSA due to heightened awareness of the condition. The proportion of persons with OSA who are asymptomatic or have unrecognized symptoms is unknown but a recent review estimated that 80% of individuals with AHI ≥5/hour may be undiagnosed.^11^ The cost burden of diagnosing and treating OSA in the US in 2015 was estimated to be $12.4 billion while the cost burden of undiagnosed OSA in the US in 2015 was estimated to be $149.6 billion when costs of comorbidities and mental health, motor vehicle accidents, workplace accidents, and lost productivity were considered.^11^ The authors acknowledged the difficulty of determining exact costs.

A prior evidence report and accompanying clinical practice guideline by the American College of Physicians (ACP) recommends that clinicians should target their assessment of OSA to individuals with unexplained daytime sleepiness.^12–14^ This is largely because evidence is lacking on the effect of CPAP on improving many other outcomes, including diabetes, coronary heart disease events, and mortality, especially among individuals without daytime sleepiness. Furthermore, the ACP concluded that assessment of OSA in the absence of daytime sleepiness and treatment of persons with low AHI are both low-value care because evidence to date indicates that neither improves clinical outcomes.

A draft evidence report and recommendation statement from the US Preventive Services Task Force (USPSTF) indicated that evidence was insufficient to assess the net benefit of screening for and treatment of asymptomatic OSA.^15^

Specifically, the most evidence was available on CPAP and found that compared to sham intervention, CPAP reduced AHI, ESS score, and blood pressure. Although studies generally showed that treatment with CPAP reduced AHI to near-normal levels, the clinical significance of the small reductions in ESS score and blood pressure is uncertain. Further, given that most of the trials were conducted in referred patients or patients of sleep clinics, the applicability of this evidence to a screen-detected population (ie, detection of abnormal AHI in asymptomatic individuals or those without excessive daytime somnolence, including based on findings from “screening” questionnaires) is limited. Despite the consistent observational findings of an association between severe OSA and increased mortality, the USPSTF identified no studies that reported on change in AHI and associated change in mortality. Thus, it is unclear whether treatments that improve AHI would also improve mortality. The USPSTF found inadequate evidence on the link between change in the intermediate outcome (AHI) and reduction in the health outcome (mortality). While the USPSTF found evidence that treatment with CPAP can improve general and sleep-related quality of life in populations referred for treatment, the applicability of this evidence to screen-detected populations is unknown. The USPSTF also found inadequate evidence on whether treatment with CPAP improves other health outcomes (mortality, cognitive impairment, motor vehicle accidents, and cardiovascular or cerebrovascular events). Following release of the USPSTF report, results from a multi-site randomized trial were published and showed that CPAP was not effective for secondary prevention of cardiovascular events in those with established cardiovascular disease and moderate to severe OSA.^16^

Despite the data associating OSA with consequences to health and quality of life and the conclusions from other guideline groups, many persons with OSA remain undiagnosed. In 2005, the National Sleep Foundation administered the Berlin sleep apnea risk questionnaire (a questionnaire commonly used for OSA screening and/or case finding) by phone to a random sample of 1,506 US adults who agreed to complete the questionnaire and found that 31% of men and 21% of women met criteria for high OSA risk.^17^ Obesity is a major risk factor for OSA and among those with a body mass index (BMI) of ≥30 kg/m^2^ (25% of the sample), 57% had high risk for OSA.

In 2010, among 1.8 million US Veterans receiving outpatient care at 136 Veterans Affairs (VA) facilities, 37.4% had a BMI ≥30 kg/m^2^, suggesting that a substantial portion of US Veterans are at high risk for OSA.^18^ A recent analysis of Veterans Administration Informatics and Computing Infrastructure (VINCI) data between 2000 and 2010 showed that among 9.8 million Veterans, the age-adjusted prevalence of diagnosed sleep apnea was 0.4% in 2000 and had increased to 3.0% in 2010 (a relative increase of 650%).^19^ As awareness of OSA by patients and providers continues to increase, and as BMI continues to increase in the US and globally,^20^ healthcare systems such as the VA need to develop strategies to manage the increasing demand for sleep services. One strategy is to target screening and testing to those most likely to derive benefit from OSA treatment (eg, those with significant unexplained daytime sleepiness), as suggested by the ACP. Another strategy is to improve efficiency within healthcare systems by implementing innovative, less resource-intense models of care for OSA.

The traditional model of OSA evaluation and care relies upon primary care providers to refer patients with suspected OSA to a sleep specialist physician (SSP) for consultation. After an initial consultative visit, the SSP can order formal, in-lab polysomnogram (PSG) for diagnostic purposes and for those with confirmed OSA, a PSG for titration of CPAP pressures. The SSP would then typically initiate CPAP at the pressure suggested by the titration PSG, and then the patient would follow up with the SSP at regular intervals for assessment of treatment compliance and efficacy. Given the rapidly rising requests for OSA diagnostic and treatment services, this traditional model is increasingly viewed as unnecessarily expensive and inefficient for the evaluation and treatment of patients at high risk of OSA. Recent data also indicate a decreasing supply of SSPs to care for patients with known or suspected OSA.^21^

Therefore, new models of OSA care have been proposed and implemented. These new models include home sleep testing (HST) for diagnostic purposes,^22^ followed by treatment with an autotitrating CPAP (APAP) device,^23^ which has internal algorithms to adjust CPAP pressure to keep the airway open during sleep. These models reduce PSG-associated costs and logistical barriers, yet typically still include consultation and follow up with a SSP. Other proposed models would reduce reliance on SSPs by including non-SSP providers such as nurses or primary care clinics to provide the bulk of OSA diagnosis and treatment.

Although several studies have been conducted to test some of these new models, systematic reviews are lacking. The Minneapolis VA’s Evidence-based Synthesis Program (ESP) Center, in partnership with topic nominators and a Technical Expert Panel (TEP), was commissioned to systematically review the evidence regarding the comparative effectiveness, harms, and cost of these new models of OSA evaluation and treatment.

We addressed the following key questions:

Key Question 1 For adults with suspected OSA, what are the effectiveness/harms/resource utilization of case finding and care provided by practitioners who are not sleep physicians (including PCPs, PAs, NPs, technologists, nurses, and respiratory therapists), compared to case finding and care provided by sleep specialist physicians?
  KQ1A Do effectiveness/harms/resource utilization vary by patient characteristics:
    a. Unexplained daytime sleepiness/fatigue
    b. AHI severity
    c. Other risk factors or coexisting conditions associated with OSA (eg, obesity, neck circumference, treatment-resistant hypertension, diabetes, age, sex, race)
    d. Symptoms (eg, nocturia, loss of libido, snoring, witnessed sleep “apnea”)?
Key Question 2 For adults with suspected OSA, what are the effectiveness/harms/resource utilization of electronic consultation versus interactive (eg, in-person, telephone) consultation?
  KQ2A Do effectiveness/harms/resource utilization vary by patient characteristics:
    a. Unexplained daytime sleepiness/fatigue
    b. AHI severity
    c. Other risk factors or coexisting conditions associated with OSA (eg, obesity, neck circumference, treatment-resistant hypertension, diabetes, age, sex, race)
    d. Symptoms (eg, nocturia, loss of libido, snoring, witnessed sleep “apnea”)?
Key Question 3 For adults diagnosed with OSA, what are the effectiveness/harms/resource utilization (including cost avoidance) of using in-home autotitrating continuous positive airway pressure (APAP) technology compared to standard continuous positive airway pressure (CPAP) titrated by in-lab PSG?
  KQ3A Do effectiveness/harms/resource utilization vary by patient characteristics:
    a. Unexplained daytime sleepiness/fatigue
    b. AHI severity
    c. Other risk factors or coexisting conditions associated with OSA (eg, obesity, neck circumference, treatment-resistant hypertension, diabetes, age, sex, race)
    d. Symptoms (eg, nocturia, loss of libido, snoring, witnessed sleep “apnea”)?

## PICOTS AND ANALYTIC FRAMEWORKS (FIGURES 1A, 1B)

Figure 1a Analytic Framework – Key Questions 1 and 2

Solid Arrow = Linkage; Dotted Arrow = Association; Curved Arrow leads to Harms (Ovals); AHI = Apnea Hypoxia Index; LIP = licensed independent practitioner; OSA = obstructive sleep apnea; PSG = polysomnography; SSP = sleep specialist physician

Figure 1b Analytic Framework – Key Question 3

Solid Arrow = Linkage; Dotted Arrow = Association; Curved Arrow leads to Harms (Ovals); AHI = Apnea Hypoxia Index; APAP = Auto-adjusting Positive Airway Pressure; CPAP = C Positive Airway Pressure OSA = obstructive sleep apnea

### Population

KQ1, KQ2 Adults with suspected obstructive sleep apnea (OSA) to include:
KQ3 Adults with diagnosed OSA

### Intervention

KQ1 supervised practitioner or non-specialist licensed independent practitioner-led care (ie, PCP, PA, NP, nurse, technologist, or respiratory therapist) (for case finding or treatment)
KQ2 Electronic initial consultation (chart review or algorithm) (for case finding)
KQ3 Home auto-titrating continuous positive airway pressure (APAP)

### Comparator

KQ1 Sleep specialist-led care (for case finding or treatment)
KQ2 Interactive (eg, in-person, telephone) initial consultation (case finding)
KQ3 In-center manual CPAP titration

### Outcomes

Intermediate Outcomes: time to initiation of therapy; compliance; apnea-hypopnea index (AHI); oxygen saturation; continuous or scale score measures of sleep symptoms, urinary symptoms, cognitive ability, weight, BMI, libido, blood pressure, or HBA1c; harms (false positives/negative, overdiagnosis, patient safety/adverse events); costs

Clinical Outcomes: mortality; resource utilization; access to care; minimally important differences in sleep symptom scores, urinary symptom scores, libido, weight change, BMI, blood pressure, or HbA1c; quality of life; diagnosis of cognitive impairment; sleep symptom score below threshold; patient satisfaction

Timing: Any

Setting: Study done in North America, Europe, or Australia/New Zealand