# APPENDIX C EVIDENCE TABLES

Table 1 Study Characteristics for KQ1

Table 2 Clinical Outcomes for KQ1

Table 3 Clinical Outcomes for KQ1, Continued

Table 4 Intermediate Outcomes for KQ1

Table 5 Intermediate Outcomes for KQ1, Continued

Table 6 Intermediate outcomes for KQ1, Continued

Table 7 Study Characteristics for KQ3

Table 8 Clinical Outcomes for KQ3

Table 9 Clinical Outcomes for KQ3, Continued

Table 10 Intermediate Outcomes for KQ3

Table 11 Intermediate Outcomes for KQ3, Continued

Table 12 Intermediate Outcomes for KQ3, Continued