# APPENDIX B PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
Yes | Thank you
Yes
Yes
Yes
Yes
Yes
No - See comments. Methods incomplete. Concepts appeared in Results and Conclusions that were omitted in the Introduction and Methods. | Thank you for the suggestions. We address the specific issues in the comments below.
2. Is there any indication of bias in our synthesis of the evidence?
No | Thank you
No
No
No
No
No
No
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
No | Thank you
Yes - Epidemiology should be updated. Consider ref Peppard Am J Epid 2013. Consider reference to cost associated with sleep apnea (Frost and Sullivan report just released, available on AASM website). The operational partner also has data on staffing, workload, and prosthetic costs related to sleep apnea, which may support the review (looking at alternative provider types to deliver sleep care, burden of disease within VA, etc.) | Thank you for the suggested references. We added the Peppard 2013 data to the Introduction. Although we typically only include data from peer review journals, we have included the Frost & Sullivan report for the AASM.
No | Thank you
No
No
No
No
4. Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
I congratulate the sponsor and the ESP team on the conduct of a methodologically rigorous evidence synthesis report on a topic of great clinical importance. | Thank you
(1) The introduction (page 1) suggests that screening is most appropriate for symptomatic patients. I agree with this suggestion. This text, and the related text on page 10, however did not mention the American Heart Association/American Stroke Association (AHA/ASA) Stroke Prevention Guidelines which recommends screening all patients with stroke for OSA (regardless of symptoms) given the robust evidence that OSA is present in the overwhelming majority of stroke patients and the evidence that treatment with PAP improves outcomes. I believe that none of the articles that were the basis of those AHA/ASA guideline recommendations would be included in this ESP review because they did not meet inclusion criteria (e.g., to my knowledge, none compared CPAP to APAP). | 1) Thank you. It is outside the scope of this review to evaluate guidelines and recommendations for screening (for example, after stroke). Our purpose in the introduction was to “set the stage” for our evaluation of alternative care models.
(2) I do not understand why dashed lines were used in the conceptual model figures from the Intermediate to the Clinical Outcomes boxes. Perhaps a legend might be added. | 2) A legend (footnote) has been added.
(3) I like the use of italics to distinguish “titration” versus “treatment” in the last question. | 3) Thank you.
(4) In non-VA settings, many facilities use standard screening tools (e.g., Berlin) to identify patients for PSG-referral (without the intervening oversight of either a primary care provider or sleep specialist). This alternative model could be mentioned in the Background or Discussion related to question 1. | 4) We have now included this as part of our expanded explanation of ‘screen-detected’ patients and noted the limited data on screen-detected patients in the Applicability and Implementation section.
(5) Given that the gaps in literature section may be useful to investigators writing IIR applications, I encourage the authors to be comprehensive in describing studies that would advance the field. For example, there are many alternative approaches to case finding (e.g., screening tools, direct use of APAP as a diagnostic test) and treatment (e.g., remote PAP monitoring, mandibular advancement devices and other approaches for PAP-intolerant patients) that merit investigation. | 5) We have expanded the gaps/future research section.
Overall excellent job with the review!! Very comprehensive and highlights important evidence gaps. | Thank you.
Under Research Gaps/Future Research: consider suggesting further evaluation on the implementation of the recommendations, not just CER of Key question 1. Key Question 2 has no published data/trials. A large pragmatic approach to studying this within the VA system is not only feasible but should be done since several programs have been using e-consults and never published outcomes. Any way to bridge this for focused HSRD would be helpful. Lastly, consider summarizing the burden of OSA, lack of providers, and clinical need for sleep medicine before wading into outcomes. This would be helpful for folks who skip to the summary directly. | We have modified the Executive Summary to include the burden of OSA and to include the discussion of Key Question 2, as we agree with the reviewer statement.
The report is excellent! I thought the Executive Summary was too long. | Thank you. We shortened the Executive Summary.
(1) It is unfortunate that the studies by Berry, Kuna and Rosen were excluded from analysis and discussion (see page 51, line 3). These are three of the most important studies in the area of alternative care models for treatment of OSA, as the models of care in practice are not restricted to home auto-CPAP versus laboratory-based CPAP titration. Efficiency of care is more strongly impacted by the use of home (HST) versus lab-based (PSG) testing. While this ESP report does not address the evidence supporting HST use as an alternative to PSG, HST use for diagnosis of OSA has become common clinical practice, especially within the VA, and these studies provide strong evidence that the HST-APAP approach achieves equivalent outcomes to the PSG-CPAP approach. This strengthens the current findings of key Question 3 regarding similarity of outcomes with APAP and CPAP. I strongly urge the authors to include a detailed analysis of these papers under Key Question 3. | 1) Thank you for the suggestion. As the reviewer notes, these studies also ‘bundled’ HST vs. PSG with APAP vs. CPAP titration, and comparing HST vs. PSG was clearly not a goal of our study. However, the APAP vs. CPAP titration data generally suggested the same findings as we found in other studies, so we have expanded our discussion about these articles. Even though they did not strictly meet our inclusion criteria,.
(2) Although it would significantly alter the scope of the report, an additional Key Question asking whether HST is a valid alternative to PSG for diagnosis of OSA would be welcome. Unfortunately, the USPSTF draft report was seriously flawed in this area, in particular failing to take into account the impact of night-to-night variation in OSA severity on PSG-HST comparisons. | 2) We are not able to alter the scope at this time. HST vs PSG could be nominated for a future ESP report.
(3) Finally, the authors correctly observe that in the studies comparing sleep specialist to non-sleep specialist care, the non-specialists generally have had additional training or experience in management of sleep apnea patients. While this important point is clearly stated under Limitations in the Evidence Report (page 50, penultimate paragraph), it is absent from the Executive Summary. As most readers will probably not get beyond the Executive Summary, it is important to include there as well, and also in the Summary of Findings for Key Question #1 on page 22. | 3) Thank you for the suggestion. We added this (and other) limitations to the Executive Summary.
Very clear layout of questions, only a few things that require clarification, major one is defining RDI- term has been used variably over time so this term needs to be defined for each study that used it, written in a very accessible way for the non-sleep specialist | Thank you for the suggestions. We made changes to clarify the text.
Page 6, line 36: Does this mean that care between the 2 groups was similar or that only the SSP group showed improvement (I think you mean the former but this is a little unclear). | Page 6. This sentence has been modified.
Page 7, line 6: RDI not defined prior to this; the definition of RDI has varied over time, for example prior to about the early 2000’s RDI was equivalent to AHI, but at time subsequently RDI has included RERAs (Respiratory Effort Related Events). Recommend that this evolution in definition as it pertains to the studies that used the term, be stated somewhere in the document. | Page 7, line 6: We added what this study reported for their RDI definition. Another study used RDI as part of a pre-test probability determination but did not define RDI.
Page 9, line 54: term “screen-detected pts” is used frequently, may be helpful at beginning of document to define this term- unclear to me if this means screened with validated measure such as a questionnaire or something else | Page 9: We have clarified this term—thank you.
Page 28, line 45: The choice of this metric ( ≥4 hours of CPAP use on ≥70% of nights) for compliance is not based on any data. Wondering if this should be explicitly stated somewhere as we don’t want to give the idea that this is # is sufficient for compliance. | Page 28. We comment in several places that measures of compliance varied. We extracted the compliance measures as reported in the included studies. We agree with the reviewer regarding the lack of evdidence for the ‘ > 4hrs for 70% of nights’ metric, but given that many studies report this (and it is used for reimbursement—we did add this statement on page 27), we felt compelled to include it.
Page 37, line 10: “Technologist time was higher on titration morning” Does this mean that physician interpretation took less time for APAP than in-lab CPAP titration? This is true and is due largely to the larger amount of data available for the in-lab studies.” | Page 37, line 10. This statement has been clarified.
Page 37, line 13: “Physician time for titration study reporting was lower in the home APAP group” This statement is also unclear. Does it mean that physician interpretation requires less time for APAP than CPAP? This is true largely due to increased information available for the in-lab studies. | Page 37, line 13. his statement has been clarified.
Table 6: Does # on front of arrow indicate the number of studies showing this result? Is this information only listed for cases where the data could not be pooled? | Table 6: Yes, the number is the number of studies. All reported outcomes are presented on the arrow tables.
• An abstract would be helpful. | -Thank you for the suggestion. An abstract has been added.
• Introduction, p. 12, lines 30–32: Provide references for estimates for OSA prevalence. | -We revised and added data from Peppard 2013.
• The distinction between intermediate and clinical outcomes is unclear. What is the difference between “weight (sic), BMI, libido, blood pressure, or HBA1c (sic)” (intermediate) and “libido, weight change, BMI, blood pressure, or HbA1c” (clinical)? | -We consider clinical outcomes to be patient-centered outcomes – something the patient can feel. Therefore, we attempt to distinguish between a change in a sleep scale score or weight (for example) and a clinically meaningful change in sleep score or weight.
• I find the limitation to English-speaking and European (do you mean Western European) countries problematic, regardless of an (unstated) interest in making applicable to the VA. Why not high income parts of Asia, Middle East, and Latin America? By North America, do you mean just US and Canada? Similarly, what is the justification for limiting to English language? Google Translate (and other methods) are highly effective. | -As described in the Limitations, our goal was to identify studies most applicable to clinical practice in the US and the VA. Regarding the non-English language studies, Google Translate has been evaluated and has not reached acceptable levels of accuracy. Standard methods for systematic reviews including through AHRQ and the ESP are to limit inclusion to articles published in English language.
• Implicitly, you have restricted to published, peer-reviewed articles. Is this the case? | -Yes. We searched MEDLINE and CINAHL.
• If ESS and SF-36 are all on the same scale (as they presumably are), why were standardized mean differences (and not weighted mean differences) used? SMD is clinically difficult to interpret. (The Cohen reference call out is missing the year). What were your minimum criteria for conducting a meta-analysis (how few studies would you meta-analyze)? | -There is no established minimal important difference for the ESS, so we used SMDs to facilitate interpretation of effect (how large was the effect based on the suggested cut points of 0.2 (small), 0.5 (moderate), and 0.8 (large)) and how precise was the estimate (if the upper or lower confidence limit crosses an effect size of 0.5 in either direction this would be considered imprecise). We will present the data as a WMD and an SMD. References have been converted to superscript format. For this review we focused our meta-analysis on ESS and SF-36 scores.
• I would suggest a much more detailed, explicit explanation for assessing the strength of evidence. Owens 2010 gives general guidance. What specifically was done here? Particularly, when and how did you determine the evidence was insufficient? Table 4 (for example) is opaque. It is unclear why strength of evidence is ranked as it is and what were the strengths and weakness of the evidence. Were directness, precision, sparseness, dose-effect, etc. assessed? Also, it would be more helpful to the reader to divide Table 4 into separate tables for each KQ. | -We added more detail in the Methods section. The strength of evidence was insufficient if no studies reported the outcome (eg, access to care) or if there was one small study with few events. Directness etc. were assessed and a table has been added (Appendix D). We divided Table 4 into separate tables for each KQ.
• Results summaries. It would be helpful to incorporate strength of evidence into the summaries. The summaries are written in a highly subjective manner, suggesting interpretation by the researchers not objective summary. Examples from KQ 1 include “good” [agreement], “similar”, and “may be”. | -Strength of evidence has been added to the summary statements at the start of each KQ. Similar is a standard term as is “may be” when evidence is very low or even low.
• The abbreviation SSP is not used consistently. | -The abbreviation is now used throughout.
• Statements such as “At baseline the patients’ average age was 55.2 years…” are unclear. This sounds like the description of a single study by appear to be a summary across the 8 studies. Where did 55.2 come from? Were the mean ages meta-analyzed? Is this the median? | -The statements are intended to provide an overview of the population in the included studies. Table 1 indicates that the values are means (unless otherwise noted) and reports the number of studies included in determining the mean. The means are weighted means. This has been added to the tables.
• In what ways were high risk of bias (and medium risk of bias) studies likely to be biased? | -Details on risk of bias are presented in Appendix C, Tables 1 and 7 (Study Characteristics)
• While the tables succinctly summarize the results of the studies, they provide highly limited data. While the Appendix tables provide the details, they are too difficult to read. I would recommend a separate set of tables in the main text that provide the summary numerical results. Also the call out to “Appendix Tables 2–3” left out which appendix (C). And the formatting of the vertical portions of the tables needs fixing. | -Thank you for the suggestion. There were a variety of measures used for the different outcomes (eg, different components of the SF-36) and then different reporting of the results (ie, mean differences, effect sizes). We thought the “arrow” tables and the Strength of Evidence tables were the best way to convery results in the text. The reference to Appendix C and the vertical alignment have been corrected.
• Figure 3 has “Mental Health” in the wrong place. It should be below the headers. Overall, the figure is unclear. It is not at all clear that the sub-analyses are in fact sub- analyses. Without close inspection, there appear to be 5 studies each for mental health and vitality (3 nurse and 2 PCP). A sub-analysis of a single study (PCP) is uninformative and misleading. The text part of the figure gives no clear distinction between the studies, sub-analyses, and overall analyses. What are the sample sizes, baseline values, follow- up times of the individual studies? Again, why is this done as a SMD and not a WMD? The figure needs a proper legend. Std diff and CI are not defined. | -The Figures have been revised for clarity deleting ‘sub-analysis” lines and additional information in the legend. WMDs are presented.
• Page 27, lines 19 and following. It is not clear why adverse events are summarized if the RCT did not provide separate data for the two treatment groups. There is no evidence to address the KQ. Also, the term treatment group is unclear for KQ 1 which compares providers not treatments. | -We agree and have modified the statements about adverse events for KQ1 throughout the report. We also changed the “treatment group” wording.
• Tables 2 and 3, with thought, partly distinguish the difference between clinical and intermediate outcomes better than the methods but the distinction seems to be more categorical vs. continuous rather than clinical vs. intermediate. Table 3 should probably better clarify that weight and BP etc. are continuous outcomes. | -As noted above, we considered weight and symptom scores as intermediate outcomes but attainment of a minimally important difference in one of those outcomes as a clinical or patient-centered outcome. We attempted to clarify in the summary statements.
• Limitations: Consider whether you are able to make any determination about possibility of bias due to the agendas of the authors. It seems plausible that studies of non- specialists vs. specialists (or home vs. lab titration which could greatly affect lab income) are being conducted by researchers with an agenda (eg, to promote non-specialists). | -We could not determine bias, but these are by nature unblinded studies. However, the reviewer raises an important issue and we now suggest (in the Executive Summary and full report) that future studies have outcomes collected in a blinded fashion where feasible.
• Research Gaps/Future Research: Consider also talking about within-study gaps, particularly related to possible reporting bias. KQ 1 and 2 are explicitly discussed in this section; why isn’t KQ 3? | - We have added some gaps/future research regarding KQ3 in this section (but only in the full report, rather than the Executive Summary—we felt that the gaps in KQ1 and KQ2 were more important for the Executive Summary). Thank you.
• Conclusions: I believe the conclusions section is the first mention of a decreasing supply of sleep physicians. | Thank you for noting this—we now discuss the decreasing supply in the introduction.