# APPENDIX A SEARCH STRATEGIES

## Ovid (Medline) KQ1 and KQ2

1. Sleep Apnea Syndromes/di,th [Diagnosis, Therapy]
2. Sleep Apnea, Obstructive/di,th [Diagnosis, Therapy]
3. (protocol: or algorithm:).mp.
4. Patient care team/or nurse’s practice patterns/or health personnel/or allied health personnel/
5. Sleep apnea syndromes/nu or sleep apnea, obstructive/nu
6. (nurse led or nurse-led).ti,ab.
7. (nurse: or nursing or technician:).mp.
8. Primary health care/or physicians/or (nurse* or technician or special* or primary care or physician).ti,ab.
9. “referral and consultation”/or (electronic adj consult).mp. or consult*.mp. or telemedicine/or remote consultation/
10. Mass screening/
11. Continuous positive airway pressure/mt, nu [methods, nursing]
12. Polysomnography/nu [nursing]
13. Chart review.mp. or risk assessment/
14. 1 or 2
15. 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13
16. 14 and 15
17. Limit 16 to (English language and yr = “2000-Current”)
18. Limit 17 to “all child (0 to 18 years)”
19. Limit 17 to “all adult (19 plus years)”
20. 18 not 19
21. 17 not 20

## Ovid (Medline) KQ3

1. Sleep Apnea Syndromes/th [therapy] or Sleep Apnea, Obstructive/th [therapy]
2. (titrat* and (manual or conventional or standard or fixed or (auto* or APAP))).mp.
3. Home care services/
4. (positive-pressure respiration/or continuous positive airway pressure/or intermittent positive-pressure ventilation/or CPAP.mp.) and (calibration/or (telemetric or titrat*).mp.)
5. 2 or 3 or 4
6. 1 and 5
7. Limit 6 to (English language and yr = “2000-Current”)
8. Limit 7 to “all child (0 to 18 years)”
9. Limit 7 to “all adult (19 plus years)”
10. 8 not 9
11. 7 not 10

## CINAHL KQ1 and KQ2

1. (MH “Sleep Apnea Syndromes/DI/TH”)
2. (MH “Sleep Apnea, Obstructive/DI/TH”)
3. AB (protocol* or algorithm*)
4. (MH “Multidisciplinary Care Team”) OR “MH “Team Nursing”) OR (MH “Total Patient Care Nursing”)
5. (MH “Nursing Practice”) OR (MH “Scope of Nursing Practice”)
6. (MH “Health Personnel”) OR (MH “Allied Health Personnel”)
7. (MH “Sleep Apnea Syndromes/NU”) OR (MH “Sleep Apnea, Obstructive/NU”)
8. “nurse led”
9. “nurse-led”
10. AB (nurse* or nursing or technician*)
11. (MH “Primary Health Care”)
12. (MH “Physicians”)
13. (MH “Referral and Consultation”) OR (MH “Remote Consultation”)
14. (MH “Telemedicine”)
15. AB (electronic adj consult) OR AB consult*
16. (MH “Health Screening”)
17. (MH “Continuous Positive Airway Pressure/MT/NU”)
18. (MH “Polysomnography/NU”)
19. 1 or 2
20. S3 OR S4 OR S5 OR S6 OR S7 OR S8 OR S9 OR S10 OR S11 OR S12 OR S13 OR S14 OR S15 OR S16 OR S17 OR S18
21. 19 AND 20 (Limits: Published dates 2000 to present, English Language)

## CINAHL KQ3

1. (MH “Sleep Apnea Syndromes/TH”) OR (MH “Sleep Apnea, Obstructive/TH”)
2. (MH “Positive Pressure Ventilation”) OR (MH “Continuous Positive Airway Pressure”) OR (MH “Intermittent Positive Pressure Ventilation”)
3. (MH “Calibration”)
4. AB “telemetric or titra*
5. 3 OR 4
6. 2 AND 5
7. AB titra* AND AB ((manual or conventional or standard or fixed or (auto* or APAP)))
8. (MH “Home Health Care”)
9. 6 OR 7 OR 8
10. 1 AND 9 (Limits: Published dates 2000 to present, English Language)