# SUMMARY AND DISCUSSION

## KEY MESSAGES

In this systematic review we found that SDM interventions for breast, colorectal, and prostate cancer screening improve knowledge and may reduce decisional conflict, but that they do not affect other measures of Decision Quality and Impact. The review suggests that SDM interventions designed to facilitate the choice of screening modality did not increase Decision Action, and SDM interventions designed to facilitate the choice of whether or not to be screened had varied effects on Decision Action. Little information exists regarding the comparative effectiveness of SDM intervention strategies, or whether the effects vary by intervention target population, key SDM intervention content/elements, patient characteristics, or cancer type. Patient receptivity to SDM interventions was generally positive as measured by stated opinions and reported reading or viewing of the intervention. Almost no data exist on providers. Additionally, no studies evaluated SDM interventions for cervical or lung cancer screening.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ1 In adults, what are the effects of shared decision making interventions for cancer screening on 1) Decision Quality; 2) Decision Impact; and 3) Decision Action?

Strength of evidence was moderate for the effect of SDM interventions for prostate cancer screening on Decision Quality; but low for the effect on Decision Impact and Decision Action. Strength of evidence was either low or insufficient for all constructs (Decision Quality, Decision Impact, and Decision Action) for both breast cancer and colorectal cancer SDM interventions (see Table 6 for a summary of strength of evidence and Appendix F for detailed information). In determining strength of evidence we only included studies that reported outcomes for a SDM intervention versus UC or placebo, including attention control, and not studies that compared one SDM intervention to another SDM intervention. For studies with multiple arms, we focused on the comparisons with UC rather than the comparisons between 2 SDM interventions. We only included data from patient-level interventions given the small number of physician-directed and multi-level interventions.

Table 6 Summary of Strength of Evidence for KQ1^a^

Outcome Category | Outcome (# of Studies Reporting) | Risk of Bias of Individual Studies | Strength of Evidence for Individual Outcomes | Strength of Evidence for Outcome Category
Breast Cancer (k=2)
Decision Quality | Knowledge (2) | Moderate | Moderate | Low
Decision Quality | Values Clarity (2) | Moderate | Low | Low
Decision Quality | Patient's Role in Decision (0) | | Insufficient | Low
Decision Impact | Decisional Conflict (1) | Moderate | Low | Insufficient
Decision Impact | Use of Services (0) | | Insufficient | Insufficient
Decision Impact | Decision Satisfaction (0) | | Insufficient | Insufficient
Decision Action | Screening Intention (2) | Moderate | Low | Low
Decision Action | Screening Behavior (1) | Moderate | Low | Low
Colorectal Cancer (k=3)
Decision Quality | Knowledge (2) | Moderate | Moderate | Low
Decision Quality | Values Clarity (1) | Moderate | Low | Low
Decision Quality | Patient's Role in Decision (1) | Moderate | Low | Low
Decision Impact | Decisional Conflict (1) | Moderate | Low | Low
Decision Impact | Use of Services (0) | | Insufficient | Low
Decision Impact | Decision Satisfaction (1) | Moderate | Low | Low
Decision Action | Screening Intention (3) | Moderate | Low | Low
Decision Action | Screening Behavior (3) | Moderate | Low | Low
Prostate Cancer (k=18)
Decision Quality | Knowledge (12) | Moderate (11); Low (1) | Moderate | Moderate
Decision Quality | Values Clarity (4) | Moderate | Low | Moderate
Decision Quality | Patient's Role in Decision (7) | Moderate (6); Low (1) | Low | Moderate
Decision Impact | Decisional Conflict (8) | Moderate (7); Low (1) | Low | Low
Decision Impact | Use of Services (1) | Moderate | Low | Low
Decision Impact | Decision Satisfaction (2) | Moderate (1); Low (1) | Low | Low
Decision Action | Screening Intention (7) | Moderate | Low | Low
Decision Action | Screening Behavior (10) | Moderate (8); Low (2) | Low | Low

a Strength of evidence determined for patient-directed interventions with a usual care or attention control group

### KQ1a Are there differential effects of the interventions based on: 1) The intervention target population (eg, provider-focused, patient-focused, system/organizational focused, multi-level); 2) Key content/elements of the intervention (eg, format, values clarification exercise, risk communication method); 3) Patient characteristics (eg, race, gender, age, health literacy); and 4) Cancer type (eg, breast, cervical, colorectal, prostate, lung)?

The majority of the included RCTs were patient-directed SDM interventions, with 2 exceptions, one clinician-level intervention and one multi-level intervention. The practitioners in the clinician-level intervention group had significantly higher knowledge, greater inclination not to order PSA, and lower PSA ordering rates after 6 weeks. The multi-level intervention did not affect patient outcomes; however, physicians participating in the clinician-level intervention appeared more neutral regarding PSA recommendations compared to physicians in the control condition.

The majority of RCTs included SDM interventions that were paper-based (14 studies) or web-based (7 studies). There were no differential effects by format.

Values clarification exercises were a positive contribution; RCTs with SDM interventions including a values clarification exercise reported a decrease in decisional conflict more often than those evaluating SDM interventions without a values clarification exercise. The outcome results did not differ for interventions that specified versus did not specify the method of risk communication.

A number of SDM interventions (10 studies) considered low health literate users in the intervention development stage, testing the intervention and then modifying it to be accessible by a low-literate audience, and a minority of these (3 studies) developed low-literacy-specific interventions. One study compared use of a SDM intervention in a low health literacy site to use in a high health literacy site, finding increased knowledge for participants at both sites.42 Only one study targeted its intervention towards a racial/ethnic group, focusing on African American men and prostate cancer screening SDM.33 Studies set in inner-city clinics had a majority of African American participants.

Breast, colorectal, and prostate cancer screening decisions are different at their core, in their population, timing, and decision type, and therefore we are unable to compare decision outcomes across cancer types.

### KQ2 Within the included studies, what is the receptivity to shared decision making interventions for: 1) Patients and 2) Providers?

Several of the included studies reported on patient receptivity to shared decision making interventions including use of the interventions or content of interventions. Patients' ratings of the intervention content reflected positive reactions and reports that the intervention materials were balanced. One study assessed the effect of a SDM intervention change on provider receptivity to SDM, finding a decrease in the proportion of the intervention group supporting passive patient decision making.30 This suggests that SDM interventions improve physicians' acceptance of SDM.

### KQ3 Within the included studies, what are the resources required to implement a shared decision making intervention?

The most human resource-intensive SDM interventions were the provider-level (1 study) and multi-level (1 study) interventions, as well as those involving patient counseling sessions in person (3 studies) or on the telephone (1 study). One study specifically detailed the financial resources required of both a moderate-cost SDM intervention (mailed video) and a low-cost SDM intervention (mailed pamphlet). The lower-cost intervention either performed equally or outperformed the moderate-cost intervention, though we caution against generalizing the results from a single study. Web-based SDM interventions (7 studies) required technological resources such as programmers and bandwidth, but web-based interventions did not consistently outperform paper comparators. Interventions using in-clinic videos and laptops also required technological resources but intervention effectiveness did not vary by resource intensity.

## PREVIOUS REVIEWS

A number of reviews have been published on both SDM and cancer screening DAs, all of which were used in our literature search.62-74 Our review is unique because it expanded the review beyond DAs, including SDM interventions such as telephone counseling, but focused specifically on cancer screening. Additionally, by anchoring our search strategy in the ODSF, our review excluded studies that promoted a specific screening decision and included studies that focused on the decision making process. Finally, we presented key components of SDM cancer screening interventions that previous reviews have not looked at, such as inclusion of values clarification exercises and method of risk communication, to provide an overview of the state of SDM interventions.

## CLINICAL SIGNIFICANCE

Despite limitations in the existing literature our findings provide important clinical information. The available information suggests that SDM interventions can improve patient knowledge but have mixed and limited effect on other aspects of Decision Impact, Quality, and Action. To aid in future dissemination of SDM interventions, this review identified studies that specified the human resources required for intervention implementation, including physician time. Clinician interest in shared decision making is critical to the implementation of SDM interventions, though many barriers exist.67

## LIMITATIONS

Our findings are limited to a large extent by the existing literature. We identified no studies assessing SDM for cervical or lung cancer. We also found few RCTs of SDM interventions for breast and colorectal cancer screening, especially comparative effectiveness trials. Because our strict criterion required studies to be RCTs and to assess either Decision Quality or Decision Impact, we excluded many quasi-experimental SDM intervention studies and other potentially relevant SDM interventions based on their limited choice of measures. As with any systematic review, our search may have been subject to publication bias. To mitigate this, we used comprehensive search terms, searched several large databases linked to different disciplines in which the topic is studied, hand searched high-priority journals and reference lists, and sought input from our TEP members and peer reviewers. However, it is possible that relevant, unpublished data exist or that papers may have been missed, either published in a language other than English or in abstract form only. Finally, we acknowledge that the included studies did not use consistent outcomes, or consistent outcome measures. The most commonly used measure was the Decisional Conflict Scale.54 Generally, study authors created their own assessments of knowledge. Therefore, we were not able to perform a meta-regression to assess heterogeneity.

## APPLICABILITY OF FINDINGS TO THE VA POPULATION

Our review revealed gaps in VA SDM cancer screening intervention research and provides a roadmap for future efforts. Only 2 studies specifically targeted a VA population; both were SDM interventions for prostate cancer screening.35-37 The first study included male Veterans aged 50 and older in general medicine clinics at 4 VA facilities.35,36 This comparative effectiveness trial compared a pamphlet DA to a video DA to UC. This SDM intervention has been widely distributed within the VA, and is available online. The second study included Veterans aged 50-80 at a VA Medical Center outpatient clinic.37 This effectiveness trial compared a pamphlet DA to a basic prostate cancer screening brochure.

SDM interventions for cancer screening did more good than harm, increasing knowledge and, more often than not, decreasing decision conflict. Although included trials were predominately outside of a VA setting, the findings are applicable to both current (eg, prostate cancer) and future (eg, lung cancer) VA decision making intervention efforts. Developing VA-specific SDM interventions, which address the particular characteristics of the population, will require commitment to the SDM medical model as well as an understanding of the current SDM field. These findings are especially relevant as VAs pilot lung cancer screening programs and develop associated patient materials. This outline of the effects of and required resources for SDM cancer screening interventions to date will help guide VA use and development of such interventions.

## RESEARCH GAPS/FUTURE RESEARCH

Research gaps remain in the field of SDM cancer screening interventions. First, there is a lack of SDM interventions for cervical and lung cancer. Given the potentially values-sensitive nature of the new recommendations for both cancers, there is a need to develop such interventions. Second, given the varying healthcare systems of, and level of enthusiasm for, cancer screening in different countries, it is particularly important to develop country- and culturally-specific SDM interventions. For instance, only recently has a DA to facilitate breast cancer screening decisions been developed in the United States; however, its quasi-experimental design excluded the study from this review.76 Third, surprisingly few (2) trials were either clinician-level or multi-level. SDM is ideally achieved by both members of the patient-health professional dyad.77 This points to a great gap in current SDM intervention research; multi-level SDM interventions that target both clinicians and patients have the potential to change healthcare professionals' decision making processes and receptivity to shared decision making, as well as support patient SDM. Additionally, neither patient literacy nor cultural competency was addressed in the majority of SDM interventions, a general criticism of decision support tools. Given the cultural differences in decision making values, cross-cultural research is called for in SDM intervention development and measurement.

In addition to addressing the gaps revealed by this systematic review, future research should focus on identifying best practices to disseminate SDM interventions and measure outcomes to allow for consistent evaluation across trials. There is also a need to address the impact of SDM interventions on additional outcomes, including relevant health outcomes (in addition to the immediate screening decision) and measures of the concordance between patients' preferred level of participation in decisions and their actual level of participation. In addition to subjective measures, investigators are developing objective measures of SDM between the patient and the clinician.78,^79^ Such measures can standardize the SDM process and aid clinician training. Finally, many of our included SDM interventions were developed and evaluated prior to the most recent guideline changes for each respective cancer. Investigators need to both update existing SDM interventions to reflect current guidelines, as well as develop new ones that address such changes.

## CONCLUSIONS

SDM interventions for breast, colorectal, and prostate cancer screening improve knowledge, but there is low to insufficient evidence that they affect other measures of Decision Quality. SDM interventions had varied effects on Decision Impact and Action, with no consistent effect on screening behavior. Little information exists regarding the comparative effectiveness of SDM intervention strategies, or whether the effects vary by intervention target population, key SDM intervention content/elements, patient characteristics, or cancer type. No studies evaluated SDM interventions for cervical or lung cancer screening. While SDM is widely viewed as an important patient-centered approach to preference-sensitive decisions, current evidence does not clearly demonstrate that studied approaches have consistent effects beyond increasing patient knowledge. Future research is needed to identify interventions that can effectively and efficiently improve patient Decision Quality and Impact across a wide range of cancers and screening strategies.