# RESULTS

We identified 26 references for inclusion, representing 23 unique trials of SDM interventions in breast (k=2), colorectal (k=3), and prostate cancer (k=18) screening. No SDM interventions for cervical or lung cancer screening met our inclusion criteria. We grouped the studies by cancer and addressed the key questions for each condition. All studies reported on Decision Quality and either Decision Action or Decision Impact.

## LITERATURE FLOW

As shown in our literature flow diagram (Figure 2), we reviewed 2,368 titles and abstracts from the electronic searches. After excluding 2,272 abstracts that did not meet our inclusion criteria, we retrieved 96 full-text articles for further review. Using our inclusion/exclusion criteria we excluded another 72 references, leaving 24 references eligible for inclusion. From our hand search we reviewed 40 full-text articles and identified 2 additional articles by hand search (eg, review of citations in previously identified articles, suggestions from reviewers), for a final 26 references of 23 unique studies.

Figure 2 Literature Flow Diagram

## KEY QUESTION #1 In adults, what are the effects of shared decision making interventions FOR CANCER SCREENING on 1) Decision Quality; 2) Decision Impact; and 3) Decision Action?

### Overview of Findings

RCTs evaluated SDM interventions in breast (k=2),19,20 colorectal (k=3),21-24 and prostate (k=18)25-44 cancer screening. Studies ranged in size from 95^21^ to 1,879^39^ participants. The duration of the SDM intervention to follow-up periods varied, ranging from immediately post-intervention delivery to 13 months.39 Studies were predominately set in General Medicine clinics and were predominately completed in the United States; however, there were also studies from Australia,19,20,24,29,30 Canada,25 and the United Kingdom.26,43 See Appendix D Evidence Tables for detailed study information.

Almost all studies measured screening behavior (k=19) and knowledge (k=19), the latter most often with a measure the investigators created. Use of services was rarely assessed (k=l). See Figure 3 for an overview of the outcomes in the included RCTs and Appendix E for a summary of the measures.

Figure 3 Overview of Outcomes in Included RCTs

#### Effect on Decision Quality

Overall, SDM interventions had a small but promising effect on most measures of Decision Quality. Participants given SDM interventions consisting of paper or DVD DAs to facilitate selection of colorectal cancer screening method had higher knowledge scores (2 of 3 studies), but the SDM interventions did not affect other Decision Quality measures including values clarity (1 study) or patients' participatory role in decision making (1 study). SDM interventions designed to facilitate decisions about whether to be screened for breast cancer in women who are younger (< 50 years of age) or older (> 70 years of age) than typically recommended for screening resulted in higher knowledge scores (2 of 2 studies). The intervention effect on values clarity was measured a number of ways; intervention groups had either increased values clarity (1 study), or there was no intervention effect (1 study), and reported lower indecision about screening mammography (2 studies). Participants given SDM interventions to facilitate decisions about whether to receive prostate cancer screening (10 of 14 screening with the prostate specific antigen [PSA] test only) consistently showed higher knowledge scores (14 studies), and improved (6 studies) or had no effect on (4 studies) patient participation in decision making. Interventions either improved measures of values clarity (3 studies) or had no effect (1 study).

#### Effect on Decision Impact

Overall, SDM interventions had varied effects on Decision Impact. SDM interventions to facilitate selection of colorectal cancer screening method improved Decision Impact with intervention groups reporting lower decisional conflict (1 study) and greater decision satisfaction (1 study). The SDM intervention designed to facilitate decisions about whether women who are older than typically recommended for breast cancer screening should be screened for breast cancer had no effect on its Decision Impact measure, decisional conflict (1 study). SDM interventions to facilitate decisions about whether to receive prostate cancer screening either led to lower (7 unique studies, plus one-half of study population of a single study), or had no effect on (2 unique studies, plus one-half of study population of a single study), decisional conflict. Such interventions also resulted in greater (1 study) or had no effect on (1 unique study, time 2 of a second study) decision satisfaction. Only one study assessed use of health care services in populations exposed to prostate cancer screening SDM interventions; this intervention had no effect.

#### Effect on Decision Action

SDM interventions designed to facilitate the choice of screening modality had varied effects on Decision Action. Specifically, SDM interventions to facilitate selection of colorectal cancer screening method either lead to greater colorectal cancer screening intention or behavior (1 study), or had no effect (2 studies). SDM interventions designed to facilitate the choice of whether or not to be screened had varied effects on Decision Action. SDM interventions to facilitate decisions about mammography decreased the proportion of younger women (age 38-45 years) who intended to start screening mammography (1 study) and had no effect on the proportion of older women (age 70-71) who either intended to or actually did stop screening mammography (1 study). SDM interventions to facilitate decisions about whether to receive prostate cancer screening lowered screening intention (5 studies) or behavior (7 studies), showed no intervention effect (3 studies and 7 studies, respectively), or, in one case, increased prostate cancer screening behavior.

Study results are presented by cancer type below, with prostate cancer screening studies further categorized by study design: 1) effectiveness trials, or studies that compared a SDM intervention to UC,29,30,37,40,41,43 2) comparative effectiveness trials, or studies that compared a SDM intervention to one or more separate SDM interventions, with or without a UC group 26,27,28,31,32,34,35,36,39,42,44 and 3) attention control trials, studies that compared a SDM intervention to an intervention similar in format but focused on a topic other than cancer screening.25,33,38 An overview of findings is presented in Table 1; evidence tables with details of study characteristics and outcomes for each included study can be found in Appendix D.

Table 1 Overview of Findings

AUTHOR, YEAR | DECISION QUALITY | | | DECISION IMPACT | | | DECISION ACTION
AUTHOR, YEAR | Knowledge | Values Clarity | Patient's Role in the Decision | Decisional Conflict | Use of Services | Decision Satisfaction | Screening Intention | Screening Behavior^a^
BREAST CANCER
Mathieu, 2007^19^ | ↑ | ↓^b^ ↓ Indecision | | ↔ | | | ↔ | ↔ 1 Month
Mathieu, 2010^20^ | ↑ | ↔ ↓ Indecision | | | | | ↓
COLORECTAL CANCER
Dolan, 2002^21^ | | | ↔ | ↓ | | | ↔ | ↔ 2-3 Months
Schroy, 2011^22^ Schroy, 2012^23^ | ↑ | | | | | ↑ | ↑ | ↑ 1 year
Trevena, 2008^24^ | ↑ | ↔ | | | | | ↔ | ↔ 1 Month
PROSTATE CANCER
Effectiveness Trials
Gattellari, 2003^29^ | ↑ | ↔ | | ↓ | | | ↔
Gattellari, 2005^30^ | ↑ | | ↑ | ↓ | | | ↓ propensity to order PSA | ↓ #PSA ordered 6 weeks
Schapira, 2000^37^ | ↑ | | | | | | | ↔ PSA & DRE 2 weeks
Volk, 1999^40^ Volk, 2003^41^ | ↑ | | | | | ↔ | ↓ (1999) | ↓ 1 year (2003) ↔ DRE
Watson, 2006^43^ | ↑ | ↑ | ↔ | | | | ↔
Comparative Effectiveness Trials
Evans, 2010^26^ | ↑ | | | ↓ | | | ↓ | ↓ 6 months
Frosch, 2003^27^ | ↑ | | | | | | | ↓ Immediately
Frosch, 2008^28^ | ↑ | ↑ | | ↓ | | | | ↓ PSA requests
Kripalani, 2007^31^ | | | ↑ | | | | | ↑ PSA requests Immediately
Krist, 2007^32^ | ↑ | | ↑ | ↔ | ↔ | | | ↓ Immediately
Myers, 2011^34^ | ↑ | | | ↔ | | | | ↔ 4 months
Partin, 2004^35^ Partin, 2006^36^ | ↑ | | ↑ | | | | ↓ | ↔ 2 weeks and 1 year (2004)
Taylor, 2013^39^ | ↑ | | | ↓ | | ↑time1 ↔ time2 | | ↔ PSA & DRE 13 months
Volk, 2008^42^ | ↔ | | ↔ | ↔ high lit^c^ ↓ low lit^c^
Wilkes, 2013^44^ | | | ↔ | | | | | ↔^d^
Attention Control Trials
Davison, 1999^25^ | | | ↑ | ↓ | | | | ↔^d^ PSA & DRE (unclear time frame)
Lepore, 2012^33^ | ↑ | | ↑ | ↓ | | | ↔ | ↔ 1-2 years
Sheridan, 2012^38^ | ↑ | ↑ | ↔ | | | | ↓ | ↓ Immediately, 9 months

↑ = SDM intervention group had higher outcome measure; ↓ = SDM intervention group had lower outcome measure; ↔ = SDM intervention had no effect on outcome measure; DRE = digital rectal examination, PSA = prostate specific antigen

a Screening is PSA only unless otherwise noted

b Lower scores indicate clearer values

c Low literacy version (10 item) of Decisional Conflict Scale (DCS) used at low literacy site and standard 16-item version used at high literacy site - scores across sites should not be compared

d Study reported no difference but no statistical results

### SDM Interventions Included in Systematic Review

#### Breast Cancer

##### Breast Cancer Screening SDM

Given the overall effectiveness of mammography for women ages 50-70,^3^ the central breast cancer screening issues to be addressed with SDM are whether to start screening below the age of 50 and whether to stop screening above the age of 70 (or at any age when there is less than a 10-year life expectancy). There has been a push to make the mammography screening decision a shared decision that is informed by patient values and preferences.58

##### Key Findings

- SDM Interventions were mailed or online DAs.
- SDM Interventions increased knowledge, but had a varied impact on other Decision Quality and Decision Impact measures.
- SDM Interventions had an effect on whether women made a decision, decreasing indecision and intention to start mammography screening, but had no effect on intention to stop mammography screening.

##### Study, Patient, and SDM Intervention Characteristics

Two trials assessed the effects of a breast cancer screening SDM interventions.19,20 Study and patient characteristics are summarized in Table 2 below and detailed in Appendix D. Both trials focused on age groups for whom there is uncertainty about the benefits of breast cancer screening and who are outside the ages typically recommended for screening, and both consisted of a single educational session and a DA.

Table 2 Summary of Study and Patient Characteristics for Breast Cancer Trials

Characteristic | Mathieu 2007^19^ | Mathieu 2010^20^
Total number of patients randomized | 734 | 511
Total number of patients evaluated | Up to 712 for questionnaire; 710 for screening outcome | 302 for knowledge; 201 for informed choice analysis
Study withdrawals, % of patients | 3% did not return questionnaire | 19% withdrew before randomization; 22% of those randomized subsequently withdrew
Age of subjects, years | 70^a^ | 42^b^
Gender, male, % of patients | 0 | 0
Race/ethnicity, white, % of patients | NR | NR
Previously screened, % of patients | 100 | 11
Studies conducted in Australia, % of patients | 100 | 100

NR=not reported

a Study enrolled women 70-71 years of age

b Study enrolled women 38-45 years of age

The first trial19 included women aged 70-71 years not previously diagnosed with breast cancer and due for their next mammogram within the next 3 months. Eligible women were randomized to receive either a DA SDM intervention or UC. The self-administered, paper booklet DA consisted of breast cancer screening information, the potential outcomes of choosing to be or not to be screened, a values clarification worksheet, and an appendix with examples of how other women completed the values clarification worksheet. After completing the DA, participants completed a questionnaire and mammography participation was assessed one month later. The second trial20 included women aged 38-45 years not previously diagnosed with breast cancer. Eligible women were given a web-based baseline questionnaire and then randomized into either immediate or delayed (control group) access to a DA SDM intervention. The DA provided age-related information regarding breast cancer screening, potential benefits and harms of screening before age 50, and a values clarification worksheet with examples of how to complete the worksheet. Intervention participants were then given access to the web-based DA worksheet and completed a questionnaire. Control subjects were immediately directed to the outcome questions upon randomization and given delayed access to the DA upon completion.

##### Outcomes

Decision Quality: Knowledge and values clarity were measured in both studies (for a description of measures see Appendix E). Mathieu et al19 showed an effect of the SDM intervention on knowledge, with 77% of the intervention group having adequate knowledge of breast cancer screening (defined by authors as 6 or more correct questions out of 10), compared to 57% of controls (χ^2^=31.15, P = .02). Seventy-four percent of women in the intervention group were considered to have made an ‘informed choice’ (as defined by demonstrating adequate knowledge and clear values towards screening that matched the intention to either continue or stop mammography screening) compared to 49% of controls (χ^2^=37.92, P < .001). Similarly, Mathieu et al20 showed a greater proportion of intervention participants than control participants with adequate knowledge (94% vs 83%, χ^2^=7.25, P = .01). Concerning values clarity, Mathieu et al19 showed women in the intervention group had clearer values about mammography than controls (as indicated by lower scores on a scale ranging from 0-100, where scores <25 indicate “clear” values) though absolute differences were small (mean 19.5 vs 22.6, respectively, T_545_=2.27, P = .02). However, in the later study there was no statistically significant difference in the proportion of women who had clear values towards mammography20 Both studies measured indecision, a marker of having clear values, and both SDM interventions reduced the proportion of women undecided in the intervention groups as compared to control groups (2007: 5% vs 10%, OR 0.32 [95% CI 0.17, 0.63], P < .001; 2010: 18% vs 39%, χ^2^=15.72, P < .001).19,20

Decision Impact: Mathieu assessed decisional conflict and found that the SDM intervention did not affect this outcome compared to a control.19

Decision Action: Both studies measured intention to either start or stop screening. Although there was no intervention effect on intention to stop screening,19 women given a SDM intervention were less likely to intend to start mammography screening (52% intervention group vs 65% control group, χ^2^=4.00, P = .05).20 Mathieu 2007 also measured screening outcomes one month post-intervention and found that SDM had no effect on having made or planning to make a mammography appointment.19

#### Colorectal Cancer

##### Colorectal Cancer Screening SDM

Colorectal cancer screening reduces colorectal cancer incidence, morbidity, and mortality and is recommended.7 However, multiple effective screening modalities exist which have different schedules and associated harms and benefits. Decisions about which screening modality to use and when to discontinue screening lend themselves to a SDM approach.

##### Key Findings

- Paper or DVD DA SDM interventions about screening modalities increased knowledge, but did not affect other measures of Decision Quality.
- SDM interventions had a small effect on Decision Impact.
- SDM interventions had mixed effects on Decision Action.
- No SDM interventions evaluated colorectal cancer screening discontinuation.

##### Study, Patient, and SDM Intervention Characteristics

Three unique RCTs of colorectal cancer SDM interventions met inclusion criteria, represented by 4 references. Study and patient characteristics are summarized in Table 3 below and detailed in Appendix D.

Table 3 Summary of Study and Patient Characteristics for Colorectal Cancer Trials

Characteristic | Mean (range) Unless otherwise noted | Number of trials reporting
Total number of patients evaluated | 1236 (97 to 825) | 3
Study withdrawals, % of patients | 11 (2 to 14) | 2^a,b^
Age of subjects, years | 66 | 1
Age of subjects <65 years, % of patients | 84 | 1^b^
Age of subjects ≥65 years, % of patients | 16 | 1^c^
Gender, male, % of patients | (41 to 48) | 3
Race/ethnicity, white, % of patients | (34 to 98) | 2^d^
Previously screened, % of patients | (13 to 27) | 2^a,c^
Studies conducted in United States, % of patients | 75 | 2^a,c^
Studies conducted in Australia, % of patients | 25 | 1^b^

a Dolan 2002^21^

b Trevena 2008^24^

c Schroy 2011/2012^22,23^

d 62% of the participants in the Schroy 2011/2012^22,23^ trial were African American

Dolan tested a pre-clinic appointment interview plus printed DA SDM intervention against a pre-clinic appointment interview plus general printed educational materials on colorectal cancer screening modalities.21 A post-visit questionnaire assessed whether the patient and physician discussed colorectal cancer screening and which screening modality the patient had chosen, if any. A follow-up chart review 2-3 months later evaluated Decision Action outcomes. Similarly, Schroy compared the effectiveness of 2 different SDM interventions (intervention 1: an audio-visual DA outlining different colorectal cancer screening modalities; intervention 2: the same DA plus a personalized risk assessment tool, Your Disease Risk [YDR]) and a UC control group given general health promotion materials.22,23 A post-visit questionnaire and a 6- and 12-month follow-up assessed which colorectal cancer screening test was completed, if any. Trevena tested a DA SDM intervention about FOBT for colorectal cancer screening against a UC control group given a government consumer guidelines booklet. A one month follow-up telephone interview assessed outcomes, including FOBT use.24

##### Outcomes

Decision Quality: SDM interventions improved patient knowledge, but not other measures of Decision Quality. Using different tests to assess knowledge, both Schroy22,23 and Trevena24 reported a significant improvement in knowledge scores in all the SDM intervention groups compared to control groups. Schroy demonstrated that both intervention groups had larger increases in knowledge scores from pre-test to post-test and versus controls, both at 6 months (mean change DA: 3.2 vs YDR: 3.1 vs control: 1.1; d=1.15, P < .001)22 and 1 year (mean change DA: 3.0 vs YDR: 3.0 vs control: 1.1; d=1.27, P < .001).23 However, there was no significant difference between the 2 interventions at either time point.22,23 The DA SDM intervention improved knowledge about FOBT screening compared to controls (20.9% vs 5.8% adequate knowledge; P = .0001).24 Trevena also examined values clarity as a subscale of the Decision Conflict Scale (DCS) and found no significant effect; however, there was an intervention effect on integrated knowledge and values, defined as both clear values and adequate knowledge (10.4% vs 1.5%, P = .002).24 Dolan measured preference for patients' role in the decision and perceptions on how the decisions were made, but found no differences.21 Standard mean differences23 and risk ratios24 for knowledge and risk ratios for perception of how screening decisions were made21 are presented in Appendix G.

Decision Impact: SDM had a small effect on Decision Impact. Dolan reported that the SDM intervention group had significantly lower decisional conflict, indicated by a lower DCS score of small magnitude compared to the control group (1.83 (0.52) vs 2.03 (0.81), effect size=0.29, P = .01).21 Schroy reported both intervention groups had significantly higher mean scores on the Satisfaction with the Decision Making Process Scale compared to the control group at both 6 months (mean score DA: 50.7 vs YDR: 50.5 vs control: 46.7; P < .001)22 and 1 year (mean score DA: 49.7 vs YDR: 49.0 vs control: 45.5; P < .001).23 See Appendix G for standard mean differences for these outcomes.

Decision Action: SDM had mixed effects on Decision Action. Baseline screening intention was high amongst all the study populations and remained high after SDM interventions. Neither Dolan21 nor Trevena24 reported a significant difference between intervention and control groups on screening intention. However, intervention patients in the Schroy study had higher scores on a measure of intention (measured from l=very unsure to 5=very sure) to schedule colorectal cancer screening compared to the control group at both 6 months (DA: 4.4 vs YDR: 4.3 vs control: 3.9; P < .001)22 and 1 year (DA: 4.4 vs YDR: 4.3 vs control: 3.9; P < .001)23, and a measure to complete colorectal cancer screening compared to the control group at both 6 months (on the same scale of 1 to 5, DA: 4.3 vs YDR: 4.3 vs control: 3.9; P < .001)22 and 1 year (DA: 4.3 vs YDR: 4.4 vs control: 4.0; P < .001).23 For both measures, at both time points, there was no difference between intervention groups. Neither Dolan21 nor Trevena24 reported significant differences in colorectal cancer screening behavior. However, Schroy reported test completion was higher for the DA group at 12 months (43% vs 35%, OR 1.30, 95% CI 0.90, 1.87, P = .046),23 but showed no difference between interventions. Screening intention and test ordering were lower when patient and provider screening preferences differed, regardless of patient's desired role in the decision making process. At 12 months the most commonly-ordered test was colonoscopy (79-81%), followed by Fecal Occult Blood Test (13-19%), flexible sigmoidoscopy (<2%), and barium enema. Mean differences and risk ratios for these outcomes are presented in Appendix G.

#### Prostate Cancer

##### Prostate Cancer Screening SDM

Randomized screening trials have demonstrated that any reduction in prostate cancer mortality through 10-14 years due to PSA screening is at most small (less than 1 in 1000 men screened), and screening results in harms due to diagnostic testing, overdiagnosis, and treatment.4,5 USPSTF guidelines recommend against PSA screening, concluding that the benefits do not exceed the harms, but suggest that men should not be screened without balanced information about the benefits and harms of PSA screening, and they should make an informed decision that reflects their values and preferences.6

##### Prostate Cancer Studies

Eighteen RCTs of prostate cancer screening SDM interventions (in 21 references) met inclusion criteria. Study and patient characteristics are summarized in Table 4 below and detailed in Appendix D. Study results are presented by study type: effectiveness trial, comparative effectiveness trial, or attention control trial.

Table 4 Summary of Study and Patient Characteristics for Prostate Cancer Trials

Characteristic | Mean (range) Unless otherwise noted | Number of trials reporting
Total number of patients evaluated | 9818 (100 to 1960) | 17^a^
Study withdrawals, % of patients | 13(0 to17)^b^ | 16
Age of subjects, years^c^ | 60 (54 to 70) | 15
Gender, male, % of patients | 100 | 17
Race/ethnicity, white, % of patients | 78 (8 to 97)^b^ | 14
Previously screened, % of patients | 52 (0 to 86)^b^ | 11
Studies conducted in United States, % of patients | 71 | 13

a One study enrolled providers and is not included on this table

b One study reported values for low literacy and high literacy subgroups as follows: withdrawals 40% low literacy, 16% high literacy; race (% white) 18% low literacy, 65% high literacy; previously screened 37% low literacy, 75% high literacy (mean of subgroups used in overall calculation)

c Studies typically included men in specified age range (ie, between 50 and 70 years or greater than 50 years)

All studies excluded men with a history of prostate cancer. The mean of the ages of study participants ranged from 54^29^ to 70^37^ years, and the majority of general practitioners (GPs) in the clinician-level intervention were aged 45-54.^30^ Almost all studies reported percentage of men with previous PSAs, ranging from 16%^43^ to 83%.44 Non-targeted studies included predominately white men, with the majority ranging from 56%^34^ to 100%,25,29 with one exception of an inner-city study, with the majority of participants African American (90%).31 A study from the United States targeting African descendants enrolled 77% Caribbean immigrants.33

#### Prostate Cancer – Effectiveness Trials (k=5)

##### Key Findings

- SDM Interventions improved Decision Quality measures, including knowledge and values clarity.
- SDM interventions decreased decisional conflict, but had no effect on patient satisfaction with the decision, the only other Decision Impact measure assessed.
- SDM interventions did not consistently affect Decision Action.
- Most SDM interventions were targeted to patients.
- A clinician-level SDM intervention increased GPs support of shared decision making.

##### Study, Patient, and SDM Intervention Characteristics

We identified 5 SDM cancer screening intervention effectiveness trials.29,30,37,40,41,43 These studies were conducted in the United States,37,40,41 the United Kingdom,43 and Australia.29,30 All studies but one were targeted towards patients; one study30 targeted physicians.

Schapira conducted a RCT at a VA outpatient clinic and included men aged 50-80 years.37 A pamphlet DA with information about prostate cancer screening and treatment was compared to the UC pamphlet that included basic information about prostate cancer. Follow up was post-intervention and 2 weeks after initial study visit, and screening options included both PSA and DRE. Volk targeted men aged 45-70 at a Family Medicine clinic and assessed the effect of an educational video (developed by the Foundation for Informed Medical Decision Making, Inc.) compared to a UC brochure.40,41 Outcomes were assessed at 2 weeks40 and 1 year.41 In the study from the United Kingdom, men aged 40-75 years were recruited from 11 GP practices in England and Wales.43 A brief print DA about PSA screening (SDM intervention) was compared to no intervention. In the patient-level Australian study, an evidence-based booklet distributed in general practice clinics in urban areas was compared to the UC pamphlet about prostate cancer published by the Australian government.29 Men were aged 40-70. Outcomes were assessed within 6 weeks. In the clinician-level Australian study, GPs who had ordered at least one PSA in past 12 months were recruited through 220 clinics in the New South Wales referral network.30 GPs were predominately male (75.1%). Intervention GPs were mailed information and given telephone peer coaching and education sessions. The SDM intervention was compared to UC – distribution of PSA screening guidelines. Follow-up was 0-6 weeks, depending on the outcome.

##### Outcomes

Decision Quality: SDM interventions improved knowledge in all 5 effectiveness trials. Two trials included values assessment and found mixed results. Gattellari 2003 used a measure indicating strength of agreement with reasons for and against PSA screening and found no significant difference between groups in of the strength of their favoring PSA testing.29 Watson developed a decisional balance measure to represent a person's attitudes about the relative positive aspects of the PSA test (‘pros’) versus the perceived negative aspects of the PSA test (‘cons’).43 The intervention group had a less favorable assessment of the PSA compared to the control group (score -3.5 (SE 0.9) vs +3.3 (SE 0.8), P < .0001). Gattellari 2005, showed a significant intervention effect on GPs' attitudes towards the patient's role in decision making; they were less likely to agree that patients should remain passive when making decisions about PSA screening (OR 0.11 [95% CI 0.04, 0.31]; P = .001].30 However, Watson found no intervention effect on patients' reporting of their preferred role in the decision.43 See Appendix G for standard mean differences and risk ratios for the Decision Quality outcomes.

Decision Impact: SDM interventions decreased decisional conflict, but had no effect on patient satisfaction with the decision, the only other Decision Impact measure assessed. Decisional conflict was reported in 2 studies, one patient-level study29 and one clinician-level study.30 Gattellari's patient-level study showed a lower level of decision uncertainty in the intervention group versus the control group (score 22 vs score 24 [95% CI 23.4, 25.2], P < .001).29 Gattellari's clinician-level study showed intervention groups had lower levels of personal decisional conflict compared to the control group (mean 25 [95% CI 24.5, 26.3] vs 28 [95% CI 26.6, 29.0]; P = .0002).30 One study assessed patient satisfaction with the decision, but reported no significant SDM intervention effect.40,41 Standard mean differences are presented in Appendix G.

Decision Action: SDM interventions had varying effects on Decision Action. Gattellari and Watson reported no effect on PSA intention29,43 and Schapira reported no effect on PSA behavior.37 However, Volk reported that at 2 weeks, fewer intervention subjects planned to have a PSA compared with control subjects (62% vs 80%, P = .009), and at one year fewer intervention subjects received a PSA compared with control subjects (34% vs 55%, P = .01).40,41 Clinicians receiving a SDM intervention ordered fewer PSA tests at 6 weeks follow-up (range 1-2 vs range 0-5, P < .001).30 Risk ratios for screening intention and screening behavior are presented in Appendix G.

#### Prostate Cancer – Comparative Effectiveness Trials (k=10)

##### Key Findings

- SDM interventions, primarily targeted at patients, influenced Decision Quality measures, notably increasing knowledge.
- SDM interventions had inconsistent effects on Decision Impact.
- SDM interventions had inconsistent effects on Decision Action.

##### Study, Patient, and SDM Intervention Characteristics

We identified 10 SDM prostate cancer screening intervention comparative effectiveness trials. 26-28,31,32,34-36,39,42,44 Studies were conducted in the United states27,28,,31,32,34-36,39,42,44 and the United Kingdom.26 All but one were targeted towards patients. Wilkes was multi-level and targeted both patients and physicians.44

Evans compared 2 SDM interventions (intervention 1: Prosdex, a web-based DA; intervention 2: a paper version of Prosdex) and 2 control groups (control group 1: UC with a baseline survey; control group 2: UC with no survey) to evaluate testing effects. Men over age 50 were recruited from GPs in South Wales. Follow-up was 6 months.26 Frosch recruited men over age 50 from a Preventive Medicine Clinic and compared 2 SDM interventions (intervention 1: a web-based DA; intervention 2: a video DA), with an immediate follow up.27 A later trial by Frosch et al recruited men over age 50 to compare 3 SDM interventions to UC (intervention 1: a traditional DA; intervention 2: a web-based decision support tool based on the Chronic Disease Trajectory Model; intervention 3: a combination of interventions 1 and 2).28 Kripalani recruited men age 45-70 in an inner-city clinic to 2 paper-based interventions (intervention 1: PtEd – a patient-based education handout; intervention 2: Cue – a handout encouraging prostate cancer screening discussions).31 Krist randomized men age 50-70 at a large community-based family practice center to one of 2 SDM interventions (intervention 1: a web-based DA; intervention 2: a paper version of intervention 1) or a UC group. There was immediate post-visit follow up.32 As part of the Decision Counseling Trial, Myers recruited men age 50-69 from 2 primary care practice sites and randomized them to one of 2 SDM interventions (intervention 1: Enhanced Intervention - structured decision counseling sessions about prostate cancer, mean time of 28 minutes; intervention 2: Standard Intervention - a patient satisfaction survey and generic note in chart). Outcomes were assessed during a telephone survey 7 days post-visit and a medical record review.34 Partin recruited male Veterans age over 50 from 4 VA General Internal Medicine clinics. Men were shown one of 2 SDM interventions (intervention 1: a pamphlet; intervention 2: a video developed by the Foundation for Informed Medical Decision Making, Inc.) or assigned to UC. Telephone follow up was at 1 week.35 Taylor recruited men aged 45-70 to one of 2 interventions (intervention 1: a web-based DA; intervention 2: a print-based DA).39 Volk recruited men 50-70 if they were not of African descent and 40-70 if they were African American, from 2 sites: a General Medicine clinic at a publicly funded hospital (labeled a low health literacy site) and a university-affiliated family medicine clinic (labeled a high health literacy site). At both sites participants were randomized to one of 2 SDM interventions (intervention 1: an interactive multimedia DA; intervention 2: an audio booklet without interactivity or entertainment).42 Wilkes recruited men age 55-65 from group practices and primary care networks and randomized them to one of 2 SDM interventions (intervention 1: an interactive web-based educational program for their physician; intervention 2: a multi-level intervention that included the physician intervention and a patient intervention) or UC.44

##### Outcomes

Decision Quality: SDM interventions, primarily targeted at patients, influenced Decision Quality measures, notably increasing knowledge. Knowledge was higher in the intervention group for 7 of the 8 studies that included a knowledge measure. Five studies measured the patients' role in the cancer screening decision, and 3 found intervention effects. Krist reported that, compared to the UC group, the SDM intervention group had a significantly lower proportion of patients reporting a passive role in decision making (18% UC vs 10% brochure [P = .03] and 8% web-based intervention [P= .03]).32 Partin reported that more men in the pamphlet DA group discussed PSA with their provider compared to the UC group (41% vs 32%, P = .03), but this was not different from the video DA group (35% vs 32%, P = .33).35 Kripalani reported discussions more frequently in Cue group (59% vs 50% vs 37%).31 See Appendix G for standard mean differences and risk ratios for Decision Quality outcomes.

Decision Impact. SDM interventions had inconsistent effects on Decision Impact. Studies measured decisional conflict using the Decisional Conflict Scale (such that lower scores reflect lower levels of conflict). Evans reported significantly lower decisional conflict for the online DA Prosdex compared to both the paper DA and the control survey group (40 vs 38 vs 48, P < .001).26 Frosch reported significantly lower scores for the traditional DA group on three subscales of the DCS.28 The Volk study saw a significant decrease in decisional conflict in the low literacy study site (mean score 22 vs 12, P = .04), but no significant change in the high literacy study site.42 Taylor found significantly lower decision conflict in web DA group, but this difference disappeared after 13 months.39 Krist and Myers found no significant effect.32,34 Only one study assessed use of healthcare services, finding no significant difference in consultation length.34 Appendix G contains standard mean differences and risk ratios for the Decision Impact outcomes.

Decision Action: Decision Action was measured predominately with screening behavior (9 studies); however, some studies measured intent (2 studies). Frosch reported men in the video intervention group had significantly fewer PSAs than men in the web-based intervention group at post-visit weeks/months follow-up (82% vs 92%, P < .05). In a later study, Frosch reported a greater reduction in PSA screening in the intervention groups compared to the control group.28 Krist reported men in the brochure SDM intervention group had fewer PSAs at post-visit weeks/months follow-up than the control group (85% vs 94%, P= .04), although there was not a significant difference between the web-based intervention group and the control group.32 Myers reported that, overall, there was no SDM intervention effect on PSA screening at 120 days follow-up.34 However, after stratifying the study sample by men with physicians aware of the PSA controversy and men with physicians who were not, for men with physicians aware of the controversy only, the SDM intervention did have an effect. Evans measured both PSA intention and behavior, and found men given the web-based DA, Prosdex, had lower intention to undergo PSA than men given the paper intervention or control survey (40% vs 53% vs 58%, P = .02).26 The Prosdex group was also less likely than both groups to get a PSA 6 month post-test (3% vs 9% vs 9%, P = .014).26 Partin reported no effect on screening behavior, at either 2 weeks or 1 year follow-up, but the intervention group had a lower PSA intention (video 63% vs pamphlet 65% vs UC 74%, P < .05).35,36 One study reported a significantly higher percentage of PSA tests ordered in the SDM intervention groups compared to usual care.31Taylor and Wilkes found no significant differences.39,44 See Appendix G for risk ratios for screening behavior and screening intention.

#### Prostate Cancer – Attention Control Trials (k=3)

##### Key Findings

- SDM Interventions increased knowledge, but had inconsistent effects on other Decision Quality measures
- SDM interventions decreased Decisional Conflict, the measure of Decision Impact
- SDM interventions had inconsistent effects on Decision Action

##### Study, Patient, and SDM Intervention Characteristics

We identified 3 studies that compared a SDM intervention for prostate cancer screening to attention control.25,33,38

Two studies were conducted in the United States33,38 and one in Canada.25 The study in Canada was conducted in one family practice clinic. The SDM intervention included written and verbal information about prostate cancer screening presented prior to a periodic health examination. In the control group, the discussion was about general issues.25 One of the studies from the United States was conducted at home and information about prostate cancer screening (SDM intervention) or fruit and vegetable consumption (control) was delivered by telephone.33 In the second study from the United States, conducted in 4 internal medicine practices prior to a scheduled appointment, the SDM intervention consisted of a video, a coaching session, and a brochure about prostate cancer screening.38 The control condition was an educational video on highway safety. One of the SDM interventions was based on a theoretical framework,33 2 included values clarification exercises,33,38 and one considered the health literacy of the participants.33

Mean ages of the study participants ranged from 55 years33 to 62 years.25 In the study from Canada, 100% of the participants were white and 61% reported Canadian ethnicity.25 One of the studies from the United States enrolled men of black African descent; 77% were Caribbean immigrants.33 In the second United States study, 64% of men enrolled were white, 18% were African American, and 18% were not specified.38 Two studies reported whether the men had previously been screened for prostate cancer, finding 28%^33^ and 52%^38^ had been screened.

Davison assessed outcomes immediately following the health examination with no further follow-up.25 Sheridan assessed outcomes following the SDM intervention session and following the health examination. Medical records were reviewed for approximately 9 months after the visit to determine whether participants were screened for prostate cancer.38 Lepore conducted an interview 8 months after randomization and reviewed claims data for 2 years after enrollment to identify screening completion.33 Twelve percent of the participants (59/490) did not complete the second interview; claims data were available for all participants.

##### Outcomes

Decision Quality: SDM interventions increased knowledge, but had inconsistent effects on other Decision Quality measures. Two studies reported knowledge scores. Lepore reported a significantly greater change in the percentage of correct answers on a 14-item knowledge test at 8 months post-randomization for the intervention group compared to the control group (10% vs 5%, P < .001).33 Similarly, Sheridan reported a greater percentage of participants correctly answering all items on a 4-item knowledge test compared to the highway safety video group (RR 3.63 [95% CI 1.86, 7.08]).38 Sheridan included a values assessment, whether men thought of PSA as a decision to make, and found a significant difference (64% intervention group vs 23% in control group, absolute difference 41% [95% CI 25, 57%]).38

The patient's role in the screening was assessed in 3 studies. Davison found men in the intervention group were more likely to assume an active role in decision making than men in the attention control group (a discussion about general issues) (62% vs 22%; P < .001).25 Lepore reported that a higher percentage of men in the intervention group talked to their provider about prostate cancer screening (16% vs 8%, P < .001).33 Among men who discussed PSA testing with their physician, Sheridan found no significant difference across experimental groups in the percentage of men reporting shared decisions or participation in decision making at the preferred level.38 See Appendix G for standard mean differences and risk ratios for the Decision Quality outcomes.

Decision Impact: Decisional conflict was reported in 2 studies with promising results. Davison reported lower decisional conflict in the group that received verbal and written information about prostate cancer screening than in the group that had a discussion of general issues (mean 29 vs 35, P < .0001).25 Lepore reported that men who received information about prostate cancer screening had lower levels of decisional conflict 8 months after randomization than men who received information about fruits and vegetables (mean 34 vs 40; standard mean difference -0.24 [95% CI -0.43, -0.05]).33 See Appendix G for standard mean differences for Decision Impact outcomes.

Decision Action: Screening intention was reported in 2 studies with inconsistent results. Lepore found no difference between SDM intervention and control in plan to receive a test for prostate cancer (81% in both groups when assessed 8 months after randomization; RR 1.00 [95% CI 0.91, 1.09]).33 Sheridan reported that the video/coaching/brochure group was less likely to report intent to be screened (45%) than the control group (79%) (RR 0.57 [95% CI 0.42, 0.78]).38 Each of the studies reported a screening outcome. Davison reported 28% of the intervention group and 21% of the control group underwent both a DRE and PSA test.25 Lepore reported non-significant differences in the percentages of patients with a verified PSA test at both 1 and 2 years.33 Sheridan reported patient-report of screening that occurred during the study visit as well as medical record review 9 months after the SDM intervention. Immediately following the study visit, 11% of the intervention group and 31% of the control group reported having a PSA test (RR 0.42 [95% CI 0.14, 1.24]).38 The percentage of participants with actual screening at 9 months post-intervention were 19% for the intervention group and 41% for the control group (RR 0.76 [95% CI 0.50, 0.97]). See Appendix G for risk ratios for screening intention and screening behavior.

## KEY QUESTION #1A Are there differential effects of the interventions based on: 1) The intervention target; 2) Key content/elements of the intervention; 3) Patient characteristics; AND 4) Cancer type?

### SDM Intervention Target

No studies directly compared SDM interventions with different targets (eg, patient vs clinician). Furthermore, due to the small number of clinician-directed SDM interventions and the variability in SDM interventions, we could not indirectly assess whether the effect of SDM interventions varied qualitatively according to the intervention target. Only 2 studies included clinician-directed SDM interventions. One prostate cancer screening SDM intervention targeted general practitioners in Australia who had ordered at least one PSA in the past year.30 The intervention consisted of mailed information, telephone peer coaching, and education. The SDM intervention increased practitioners' knowledge and decreased their PSA ordering rate after 6 weeks. Another prostate cancer SDM intervention trial compared a physician-level intervention with a multi-level intervention targeting both physicians and their patients.44 The multi-level SDM intervention was comprised of an interactive web education program for primary care physicians and a similar interactive web-based program for patients encouraging them to participate actively in the prostate cancer screening decision. Post intervention, patients' ratings of SDM did not differ between intervention groups. However, physicians in the multi-level SDM intervention were more neutral regarding PSA recommendations than those in the physician-level SDM intervention, being less likely to make a recommendation either for or against PSA.

### Key SDM Intervention Content

A priori, and in consultation with our Technical Expert Panel (TEP), we selected 3 key content areas and extracted SDM intervention information based on those areas: (1) intervention format; (2) values clarification exercises; and (3) risk communication method. A summary of the SDM intervention content is presented in Table 5.

Table 5 Summary of SDM Intervention Content^a^

Intervention Characteristics | Breast Cancer (k=2) | Colorectal Cancer (k=3) | Prostate Cancer (k=18)
Intervention Format - Delivery
Decision aid (DA) | Mathieu 2007^19^ Mathieu2010^20^ | Schroy2011/2012^22,23^ Dolan 2002^21^ Trevena 2008^24^ | Evans 2010^26^ Frosch 2003^27^ Frosch 2008^28^ Partin 2004/2006^35,36^ Taylor 2013^39^ Volk2008^42^
Counseling | | | Lepore 2012^33^ Myers 2011^34^ Sheridan 2012^38^
Education program | | | Gattellari 2005^30^ Schapira 2000^37^ Watson 2006^43^ Wilkes 2013^44^
Intervention Format - Delivery Mode
DVD/Videotape | | Schroy 2011/2012^22,23^ | Frosch 2003^27^ Partin 2004/2006^35,36^ Sheridan 2012^38^ Volk 2003/1999^40,41^
Web-based | Mathieu 2010^20^ | | Evans 2010^26^ Frosch 2003^27^ Frosch 2008^28^ Krist 2007^32^ Taylor 2013^39^ Wilkes 2013^44^
Face-to-face | | Dolan 2002^21^ | Sheridan 2012^38^ Myers 2011^34^
Printed | Mathieu 2007^19^ | Dolan 2002^21^ Schroy 2011/2012^22,23^ | Evans 2010^26^ Gattellari 2003^29^ Krist 2007^32^ Kripalani 2007^31^ Partin 2004/2006^35,36^ Schapira 2000^37^ Taylor 2013^39^ Volk 2003/1999^40,41^ Watson 2006^43^
Verbal & written | | | Davison 1999^25^ Gattellari 2005^30^
Telephone | | | Lepore 2012^33^
Intervention Format - Timing
In-clinic | | Dolan 2002^21^ Schroy 2011/2012^22,23^ | Davison 1999^25^ Frosch 2003^27^ Gattellari 2003^29^ Kripalani 2007^31^ Myers 2011^34^ Schapira 2000^37^ Sheridan 2012^38^ Volk 2008^42^ Wilkes 2013^44^
At home before appointment | Mathieu 2007^19^ Mathieu 2010^20^ | Trevena 2008^24^ | Evans 2010^26^ Frosch 2003^27^ Frosch 2008^28^ Krist 2007^32^ Lepore 2012^33^ Partin 2004/2006^35,36^ Taylor 2013^39^ Watson 2006^43^
Other | | | Gattellari 2005^30^
Explicit Values Clarification Exercise
None | | | Davison 1999^25^ Frosch 2003^27^ Gattellari 2005^30^ Kripalani 2007^31^ Krist 2007^32^ Partin 2004/2006^35,36^ Schapira 2000^37^ Volk 1999/2003^40,41^ Watson 2006^43^
Worksheet | Mathieu 2007^19^ Mathieu 2010^20^ | Trevena 2008^24^ | Taylor 2013^39^
Time trade-off exercise | | | Frosch 2008^28^
Discrete choice | | Schroy 2011/2012^22,23^
Analytic Hierarchy Process (Zahedi 1986) | | Dolan 2002^21^
Decision stacker | | | Evans 2010^26^
Social matching | | | Gattellari 2003^29^ Sheridan 2012^38^ Volk2008^42^
Discussion/questions of risks and benefits, values | | | Lepore 2012^33^ Myers 2011^34^ Wilkes 2013^44^
Risk Communication Method
Not specified | | Dolan 2002^21^ | Davison 1999^25^ Evans 2010^26^ Frosch 2003^27^ Frosch 2008^28^ Gattellari 2005^30^ Kripalani 2007^31^ Krist 2007^32^ Lepore 2012^33^ Myers 2011^34^ Partin 2004/2006^35,36^ Sheridan 2012^38^ Volk2008^42^ Volk 1999/2003^40,41^ Watson 2006^43^
Pictographs | Matheiu 2007^19^ Matheiu 2010^20^ | Trevena 2008^24^ | Gattellari 2003^29^ Schapira 2000^37^ Taylor 2013^39^
Web-based “Your Disease Risk” (personalized risk estimates); audio/visual | | Schroy 2011/2012^22,23^
Diagrams | | | Wilkes 2013^44^

a Comparative effectiveness trials (ie, more than 1 intervention) may have multiple characteristics

#### Intervention Format & Delivery

The majority of studies were DAs. They included paper-based (14 studies) or web-based (7 studies) SDM interventions; few were delivered face-to-face (3 studies) or by telephone (1 study). Interventions were delivered before appointments to promote SDM during the cancer screening decision process. They were predominately delivered on-site, or provided at home, either by mail or accessed on the Internet, before the appointment.

#### Values Clarification Exercises

Fourteen of 23 SDM interventions included a values clarification exercise. All of the colorectal cancer screening21-24 and breast cancer screening19,20 SDM interventions, and 9 of 18 prostate cancer screening SDM interventions26,28,29,33,34,38,39,42,44 included values clarification exercises. The types of values clarification methods varied, with no clear predominate method. The breast cancer screening SDM intervention exercises, developed by the same study team, were worksheets with examples of how to complete them. The colorectal cancer screening SDM intervention values clarification exercises were theoretically different from those of the breast and prostate cancer screening SDM interventions; these exercises helped the patient identify a screening modality preference based on his or her own values. The other SDM interventions helped patients clarify what is important to them, and how that translates into being screened for cancer or not being screened for cancer.

#### Risk Communication Method

Although effective communication of screening risks and benefits is essential to SDM interventions, few studies specified exactly how their interventions communicated risk. Studies that did predominately used pictographs.19,20,24,29,37,29 This follows earlier research that few prostate cancer DAs included any numerical information.60 The earlier Mathieu intervention used 1000-face pictograms to communicate the event rate per 1000 women screened for breast cancer with mammography every 2 years over 10 years, starting at age 70.^19^ Mathieu 2010 also included 1000-face pictograms to communicate event rates per 1000 women aged 38-45 who are not screened over 10 years in addition to those screened every 2 years.20 Wilkes used diagrams of visual risk comparison as vignettes to convey the risk for potential harms.44 Schroy used a web-based program, “Your Disease Risk”, to display personalized risk estimates.22,23 Fagerlin concluded that the most important element of risk communication is the presentation of numbers as frequencies or percentages rather than risk ratios or absolute risk.61

### Patient Characteristics

#### Race

Only one SDM intervention was developed for a specific racial/ethnic group. Lepore targeted the prostate cancer screening SDM intervention to black men of African descent.33 No other studies reported outcomes by race and ethnicity or created a SDM intervention targeted towards a specific cultural group. Most SDM interventions were not racially/ethnically diverse. However, some studies did use inner-city clinics for SDM interventions for colorectal cancer screening22,23 and prostate cancer screening.31 The percentage of white subjects for colorectal cancer screening SDM intervention studies ranged from 34% to 98%, and for prostate cancer screening SDM intervention studies from 8% to 97%.

#### Gender

All prostate cancer screening studies included only male participants and all breast cancer screening studies included only female participants; colorectal cancer screening studies ranged from 41% to 48% male, none of which examined differences in effects by gender.

#### Age

The breast cancer screening SDM intervention studies were the only 2 to directly address the issue of screening outside of the generally recommended or core age group, with one intervention targeted at women aged 38-45 years, and the second targeted at women aged 70-71. The mean age of subjects in SDM intervention studies for colorectal cancer was 66 years; 84% of subjects were less than 65 years and 16% were 65 years or older. The mean age of subjects in SDM intervention studies for prostate cancer was 61 years.

#### Health Literacy

Ten SDM interventions specified considering low health literate users in the intervention development or pilot-testing testing stage.22-24,29,31,33,35-37,39,40-42 Two of these studies specifically developed interventions for a low-literacy audience.31,33 Volk developed 2 separate SDM prostate cancer screening interventions; one for a high health literacy site (a university-affiliated family medicine clinic) and another for a low health literacy site (a general medicine clinic at a publicly-funded hospital).42 Both SDM interventions improved knowledge and the intervention developed for the low-literacy site lowered decisional conflict, although the intervention developed for the high-literacy site did not.

### Cancer Type

Breast, colorectal, and prostate cancer screening decisions are different at their core, in their population, timing, and decision type. For example, for the age group of adults 50-74 years old, colorectal cancer screening is recommended. Therefore the SDM approach for colorectal cancer screening primarily involves decisions regarding the choice between different screening modalities (typically annual FOBT or colonoscopy every 10 years). Prostate cancer screening decisions involve the choice to have a PSA or not to be screened at all. Because of differences in the inherent purposes for the SDM interventions, we were unable to compare decision outcomes across cancer types. As noted we found no studies assessing SDM for cervical or lung cancer screening.

## KEY QUESTION #2 Within the included studies, what is the receptivity to shared decision making interventions for cancer screening for: 1) patients and 2) providers?

### Patient Receptivity

Fourteen unique studies reported on patient receptivity to SDM interventions and one study reported on physician receptivity to SDM intervention.

#### Use of the SDM Intervention

In 6 prostate cancer studies, “receptivity” was measured by SDM intervention use. Frosch assigned patients to receive educational information about PSA testing either over the internet at their convenience or via video prior to their clinic appointment.27 Men in the video group were significantly more likely to view the video than completely view the presentation on the website (98% vs 54% P < .001). Nearly 40% of the web-based group did not review any of the presentation. In a subsequent study of different web-based interventions, authors monitored patient access to the DAs and sent reminders to increase compliance; 84% of all participants reviewed the interventions.28

Partin mailed male Veterans a prostate cancer DA in either pamphlet or video format.35,36 Participants were contacted by telephone and asked if they recalled receiving the DA and, if so, whether they looked at the DA. Significantly more participants recalled receiving the video (78% vs 64%, P < .01) but there was no significant difference in the percentage having looked at either the pamphlet (50%) or the video (56%). Participants who were married, had education beyond high school, and had no prior abnormal PSA tests were more likely to report use of the video. None of the patient characteristics assessed was significantly associated with use of the pamphlet.

In a study that randomized participants to a web-based DA, a paper-based version of the DA, or usual care, there was no significant difference in the proportion of participants reporting reviewing the DAs before their visit (web-based 85%, paper-based 88%).32

In a study that mailed participants a brief prostate cancer DA and a questionnaire about prostate cancer screening (knowledge, attitude, intention) or the questionnaire alone, 93% of those in the intervention group reported having read most or all of the information.43

In a study of a low-literacy handout to encourage discussions about prostate cancer screening, nearly all (99.6%) patients reported looking at the handout and most (94.6%) reported reading it.31

#### SDM Intervention Content

Patients' ratings of the SDM intervention contents regarding information bias, clarity, and helpfulness were reported in 9 studies of SDM interventions for breast, colorectal, and prostate cancer screening. One of the studies also reported on use of the SDM intervention.43 Most respondents indicated that SDM intervention content was balanced, clear, helpful, and of appropriate length and detail. Overall, participants rated materials as balanced and fair.

A SDM DA intervention designed to inform the decision by women age 70-71 years to continue or stop mammography screening and presented in booklet form was pilot tested in a group of 29 women.19 Approximately half of the women thought the information was balanced and fair, one quarter thought the information was biased toward screening, and one quarter thought the information was biased toward stopping screening. In a subsequent study of a paper-based DA for mammography screening in women 38-45 years, 49% reported that the information was completely balanced.20 Participants believed that SDM intervention material was easy to understand. The breast cancer screening SDM intervention was reported as clear by 97% and understandable by 97%^19^ and clear by 56% and understandable by 73%.20 The contents of the first breast cancer screening SDM intervention were viewed as the right length by 86% and containing about the right amount of information to make the decision by 72%;19 the second SDM intervention was viewed as the right length by 67% and containing about the right amount of information by 65%.20 The booklet was rated as “very helpful” by 44% and 47% reported they would “definitely recommend” the booklet.20

Two studies of colorectal cancer screening SDM interventions reported patients' perceptions of the contents. In one study, all patients had an in-person interview session.21 Participants in the intervention group completed a detailed analysis of the screening decision using an analytic hierarchy process while control group participants received educational materials. No significant differences were reported in mean Likert Scale responses to “Did you like the interview?” or “Doctors should use routinely”. In the second study, participants received either a DA SDM intervention or were assigned to UC and given the consumer version of government-issued guidelines for colorectal cancer screening.24 Compared to respondents in the UC group, significantly more respondents in the intervention group thought the DA they received integrated knowledge and values, provided adequate knowledge, had about the right amount of information, was about the right length, and presented completely balanced information. The groups did not differ on whether they would definitely recommend the resource.

Several of the prostate cancer studies also obtained patient evaluations of the SDM interventions. An educational video from the Foundation for Informed Medical Decision Making, Inc. was found to have about the right amount of information (79%), be the right length (86%), present most or everything clearly (88%), and be balanced (79%).40,41 Only 7% of study participants reported that their decision about screening was not at all influenced by the video and 92% would recommend that others watch the video before making a decision about PSA testing.

Another study compared a 32 page evidence-based booklet on PSA screening to a government-developed pamphlet.29 The government pamphlet was shorter and non-numeric while the evidence-based booklet included data and was designed for maximum readability. No significant differences were reported for the percentage of study participants who read all of the material, who found the information useful, or who found the information was easy to read. The groups did differ significantly on whether the amount of information was right, including whether there was the right amount of information about risk and benefits of PSA testing, and on whether they would recommend the material to a friend or relative their own age.

The study of an in-clinic video presentation versus an web-based presentation, described above, found no differences between groups in ratings of the interventions.27 Participants were asked about convenience, effort required, satisfaction with the presentations, and “overall sentiments about participating in these types of interventions.” However, overall, 81% of all participants were “somewhat” or “very positive” about their participation.

The brief DA SDM intervention evaluated by Watson was found to provide “most or all” new information to 67% of the men who received it.43 Most participants thought the information was easy to read (93%), had about the right level of detail (87%), and presented information in a “balanced way” (94%).

A study with high-literacy and low-literacy sites obtained measures of acceptability for an entertainment-based DA (interactive, multi-media approach) and an audiobooklet DA (no interactivity or entertainment components).42 Participants from the low-literacy site were less likely than those from the high-literacy site to respond that the both the entertainment-based DA and the audiobooklet had about the right amount information (51% vs 86%, P < 0.01; 59 vs 86%, P < 0.01, respectively), although they were also less likely to rate the program length of both interventions as too long (11% vs 43%, P = .00; 3% vs 5%, P < 0.01, respectively). Participants from the low-literacy site less often reported that everything was clear in the entertainment-based aid (52% vs 71%, P = .05), but no differences were noted for clarity of presentation of the audiobooklet. Finally, although there were no differences in the reported balance of the entertainment-based DA, participants at the low-literacy site were more likely than their counterparts to report the audiobooklet as “slanted toward screening” (7% vs 0%, P = .01).

### Provider Receptivity

One study assessed the effect of a SDM intervention on provider receptivity to SDM.30 General practitioners reported how much they supported the response options in the Control Preferences Scale, a measure of patients' involvement in decisions. SDM decreased the proportion of the intervention group supporting passive patient decision making (intervention group change -14.1% vs control group change +0.2%; P < .05).

## KEY QUESTION #3 Within the included studies, what are the resources required to implement a shared decision making intervention for cancer screening?

One challenge in clinic implementation of SDM interventions is required resources, for example, staff time and effort, financial commitment, and technological and facility requirements. We highlight any studies that outlined the resources required for SDM implementation. Overall, there was no evidence that more resource-intensive SDM interventions were more effective than less resource-intensive ones.

### Human Resources

There was a variety of reported staff resources in terms of time commitment and type of staff required. The most human resource-intensive patient-level SDM interventions involved patient counseling sessions, either face-to-face21,34,38 or on the telephone.33 These studies used nurse educators,34 graduate-level health educators,33 or research assistants,38 who had to be trained themselves. Some studies required that participants have assistance while completing interventions.37,44

Provider-level and multi-level SDM interventions required the most provider time, an important factor in implementing any intervention. The multi-level intervention required physician education using standardized patients – trained actors that received 20 hours of training.44 The physician-level intervention required both telephone peer coaching and medical peer educators who delivered peer coaching sessions.30

### Financial Resources

One study directly outlined SDM intervention costs. Partin specifically noted the costs of both a moderate-cost SDM intervention (mailed video) and a low-cost SDM intervention (mailed pamphlet).35,36 The cost of the intervention video was $37.00 per patient, and the cost of the intervention pamphlet was less than $2 per patient. Compared to the UC condition, knowledge increased and PSA intention decreased for both SDM intervention groups. However, there was no difference between SDM intervention groups on these measures. Patients in the pamphlet intervention group were more likely to discuss screening with their physicians than those in the video intervention group and PSA rates did not differ between groups. The low-cost SDM intervention either performed equally or outperformed the moderate-cost SDM intervention.

### Technological Resources

Few studies specifically outlined the technological resources required for the SDM interventions. However, the web-based interventions would require a certain amount of bandwidth and programming capability.20,26-28,32,39,44 Wilkes required laptop computers for study participants, to allow research assistants to assist with intervention delivery.44 Similarly, video SDM interventions viewed in the clinic would require resources such as viewing rooms, televisions, and DVD players.22,23,38,40 SDM intervention effectiveness did not vary by technological resource intensity; in fact, studies that compared web-based SDM interventions to paper ones did not consistently show web-based interventions to be superior.26,32,39