# REFERENCES

1 Pace LE, Keating NL. A systematic assessment of benefits and risks to guide breast cancer screening decisions. JAMA. 2014;311(13):1327-35. [pmid: 24691608].
2 Nelson HD, Tyne K, Naik A, Bougatsos C, Chan BK, Humphrey L. U. S. Preventive Services Task Force. Screening for breast cancer: an update for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(10):727-37. W237. 42. [pmid: 19920273].
3 Walter LC, Schonberg MA. Screening mammography in older women: a review. JAMA. 2014;311(13):1336-47. [pmid: 24691609].
4 Andriole GL, et al. PLCO Project Team. Prostate cancer screening in the randomized Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial: mortality results after 13 years of follow-up. J Natl Cancer Inst. 2012;104(2):125-32. [pmid: 22228146].
5 Schröder FH, et al., for the ERSPC Investigators. Prostate-cancer mortality at 11 years of follow-up. N Engl J Med. 2012;366(11):981-90. [pmid: 22417251].
6 Moyer VA. U.S. Preventive Services Task Force. Screening for prostate cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;157(2):120-34. [pmid: 22801674].
7 U.S. Preventive Services Task Force. Screening for colorectal cancer: recommendation and rationale. Ann Intern Med. 2002;137(2):129-31. [pmid: 12118971].
8 Woolf SH. The best screening test for colorectal cancer--a personal choice. N Engl J Med. 2000;343(22):1641-3. [pmid: 11096175].
9 Moyer VA. U.S. Preventive Services Task Force. Screening for cervical cancer: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2012;156(12):880-91. [pmid: 22711081].
10 Elwyn G, Coulter A, Laitner S, Walker E, Watson P, Thomson R. Implementing shared decision making in the NHS. BMJ. 2010;341:c5146. [pmid: 20947577].
11 International Patient Decision Aid Standard Collaboration. Background Document. 2005. Available from: http://ipdas.ohri.ca/IPDASBackground.pdf. 15 Oct 2014.
12 Légaré F, Ratté S, Stacey D, et al. Interventions for improving the adoption of shared decision making by healthcare professionals. Cochrane Database Syst Rev. May. 12. 2010;(5). CD006732.
13 O'Connor AM. Ottawa Decision Support Framework to Address Decisional Conflict ©2006. Available from: www.ohri.ca/decisionaid. 31 Aug 2014.
14 Stacey D, Légaré F, Col NF, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. Jan. 28. 2014;1. CD001431.
15 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011. Available from http://handbook.cochrane.org. 31 Aug 2014.
16 Review Manager (RevMan) [Computer program]. Version 5.1. Copenhagen. The Nordic Cochrane Centre, The Cochrane Collaboration. 2011.
17 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
18 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
19 Mathieu E, Barratt AL, Davey HM, McGeechan K, Howard K, Houssami N. Informed choice in mammography screening: A randomized trial of a decision aid for 70-year-old women. Arch Intern Med. 2007;167(19):2039-46. [pmid: 17954796].
20 Mathieu E, Barratt AL, McGeechan K, Davey HM, Howard K, Houssami N. Helping women makes choices about mammography screening: A randomized trial of a decision aid for 40-year-old women. Patient Educ Couns. 2010;81:63-72. [pmid: 20149953].
21 Dolan JG, Frisina S. Randomized controlled trial of a patient decision aid for colorectal cancer screening. Med Decis Making. 2002;22(2):125-39. [pmid: 11958495].
22 Schroy PC, Emmons K, Peters E, et al. The impact of a novel computer-based decision aid on shared decision making for colorectal cancer screening: a randomized trial. Med Decis Making. 2011;31(1):93-107. [pmid: 20484090].
23 Schroy PC, Emmons KM, Peters E, et al. Aid-assisted decision making and colorectal cancer screening: a randomized controlled trial. Am J Prev Med. 2012;43(6):573-83. [pmid: 23159252].
24 Trevena LJ, Irwig L, Barratt A. Randomized trial of a self-administered decision aid for colorectal cancer screening. J Med Screen. 2008;15(2):76-82. [pmid: 18573775].
25 Davison BJ, Kirk P, Degner LF, Hassard TH. Information and patient participation in screening for prostate cancer. Patient Educ Couns. 1999;37(3):255-63. [pmid: 14528551].
26 Evans R, Joseph-Williams N, Edwards A, et al. Supporting informed decision making for prostate specific antigen (PSA) testing on the web: an online randomized controlled trial. J Med Internet Res. 2010;12(3):e27. [pmid: 20693148].
27 Frosch DL, Kaplan RM, Felitti VJ. A randomized controlled trial comparing internet and video to facilitate patient education for men considering the prostate specific antigen test. J Gen Intern Med. 2003;18(10):781-7. [pmid: 14521639].
28 Frosch DL, Bhatnagar V, Tally S, Hamori CJ, Kaplan RM. Internet patient decision support: a randomized controlled trial comparing alternative approaches for men considering prostate cancer screening. Arch Intern Med. 2008;168(4):363-9. [pmid: 18299490].
29 Gattellari M, Ward JE. Does evidence-based information about screening for prostate cancer enhance consumer decision-making? A randomised controlled trial. J Med Screen. 2003;10(1):7-39.
30 Gattellari M, Donnelly N, Taylor N, Meerkin M, Hirst G, Ward JE. Does ‘peer coaching’ increase GP capacity to promote informed decision making about PSA screening? A cluster randomised trial. Fam Pract. 2005;22(3):253-65. [pmid: 15824055].
31 Kripalani S, Sharma J, Justice E, et al. Low-literacy interventions to promote discussion of prostate cancer: a randomized controlled trial. Am J Prev Med. 2007;33(2):83-90. [pmid: 17673094].
32 Krist AH, Woolf SH, Johnson RE, Kerns JW. Patient education on prostate cancer screening and involvement in decision making. Ann Fam Med. 2007;5(2):112-9. [pmid: 17389534].
33 Lepore SJ, Wolf RL, Basch CE, et al. Informed decision making about prostate cancer testing in predominantly immigrant black men: a randomized controlled trial. Ann Behav Med. 2012;44(3):320-30. [pmid: 22825933].
34 Myers RE, Daskalakis C, Kunkel EJS, et al. Mediated decision support in prostate cancer screening: a randomized controlled trial of decision counseling. Patient Educ Couns. 2011;83(2):240-6. [pmid: 20619576].
35 Partin MR, Nelson D, Radosevich D, et al. Randomized trial examining the effect of two prostate cancer screening educational interventions on patient knowledge, preferences, and behaviors. J Gen Intern Med. 2004;19(8):835-42. [pmid: 15242468].
36 Partin MR, Nelson D, Flood AB, Friedemann-Sanchez G, Wilt TJ. Who uses decision aids? Subgroup analyses from a randomized controlled effectiveness trial of two prostate cancer screening decision support interventions. Health Expect. 2006;9(3):285-95. [pmid: 16911143].
37 Schapira MM, VanRuiswyk J. The effect of an illustrated pamphlet decision-aid on the use of prostate cancer screening tests. J Fam Pract. 2000;49(5):418-24. [pmid: 10836772].
38 Sheridan SL, Golin C, Bunton A, et al. Shared decision making for prostate cancer screening: the results of a combined analysis of two practice-based randomized controlled trials. BMC Med Inform Decis Mak. 2012;12:130. [pmid: 23148458].
39 Taylor KL, Williams RM, Davis K, et al. Decision making in prostate cancer screening using decision aids vs usual care: a randomized clinical trial. JAMA Intern Med. 2013;173(18):1704-12. [pmid: 23896732].
40 Volk RJ, Cass AR, Spann SJ. A randomized controlled trial of shared decision making for prostate cancer screening. Arch Fam Med. 1999;8(4):333-40. [pmid: 10418541].
41 Volk RJ, Spann SJ, Cass AR, Hawley ST. Patient education for informed decision making about prostate cancer screening: a randomized controlled trial with 1-year follow-up. Ann Fam Med. 2003;1(1):22-8. [pmid: 15043176].
42 Volk RJ, Jibaja-Weiss ML, Hawley ST, et al. Entertainment education for prostate cancer screening: a randomized trial among primary care patients with low health literacy. Patient Educ Couns. 2008;73(3):482-9. [pmid: 18760888].
43 Watson E, Hewitson P, Brett J, et al. Informed decision making and prostate specific antigen (PSA) testing for prostate cancer: a randomised controlled trial exploring the impact of a brief patient decision aid on men's knowledge, attitudes and intention to be tested. Patient Educ Couns. 2006;63(3):367-79. [pmid: 16875796].
44 Wilkes MS, Day FC, Srinivasan M, et al. Pairing physician education with patient activation to improve shared decisions in prostate cancer screening: a cluster randomized controlled trial. Ann Fam Med. 2013;11(4):324-34. [pmid: 23835818].
45 Kaplan SH, Gandek B, Greenfield S, Rogers W, Ware JE. Patient and visit characteristics related to physicians' participatory decision-making style. Results from the Medical Outcomes Study. Med Care. 1995;33(12):1176-87. [pmid: 7500658].
46 Radosevich DM, Partin MR, Nugent S, et al. Measuring patient knowledge of the risks and benefits of prostate cancer screening. Patient Educ Couns. 2004;54(2):143-52. [pmid: 15288907].
47 O'Dell KJ, Volk RJ, Cass AR, Spann SJ. Screening for prostate cancer with the prostate-specific antigen test: are patients making informed decisions?. J Fam Pract. 1999;48(9):682-8. [pmid: 10498074].
48 Dormandy E, Michie S, Hooper R, Marteau TM. Informed choice in antenatal Down syndrome screening: a cluster-randomised trial of combined versus separate visit testing. Patient Educ Couns. 2006;61(1):56-64. [pmid: 16533677].
49 Rakowski W, Andersen MR, Stoddard AM, et al. Confirmatory analysis of opinions regarding the pros and cons of mammography. Health Psychol. 1997;16:433-41. [pmid: 9302540].
50 McCormack L, Treiman K, Bann C, et al. Translating medical evidence to promote informed health care decisions. Health Serv Res. 2011;46(4):1200-23. [pmid: 21352225].
51 Degner LF, Sloan JA. Decision making during serious illness: What role do patients really want to play?. J Clin Epidemiol. 1992;45(9):941-50. [pmid: 1432023].
52 Brashers DE, Haas SM, Neidig JL. The patient self-advocacy scale: measuring patient involvement in health care decision-making interactions. Health Commun. 1999;11(2):97-121. [pmid: 16370972].
53 Strull WM, Lo B, Charles G. Do patients want to participate in medical decision making?. JAMA. 1984;252(21):2990-4. [pmid: 6502860].
54 O'Connor AM. Validation of a decisional conflict scale. Med Decis Making. 1995;15(1):25-30. [pmid: 7898294].
55 Dolan JG. A method for evaluating health care providers' decision making: The Provider Decision Process Assessment Instrument. Med Decis Making. 1999;19:38-41. [pmid: 9917018].
56 Barry MJ, Cherkin DC, Chang Y, Fowler FJ, Skates S. A randomized trial of a multimedia shared decision-making program for men facing a treatment decision for benign prostatic hyperplasia. Dis Manag Clin Outcomes. 1997;1:5-14.
57 Holmes-Rovner M, Kroll J, Schmitt N, et al. Patient satisfaction with health care decisions: the satisfaction with decision scale. Med Decis Making. 1996;16(1):58-64. [pmid: 8717600].
58 Sheridan SL, Harris RP, Woolf SH. Shared decision making about screening and chemoprevention: a suggested approach from the US Preventive Services Task Force. Am J Prev Med. 2004;26(1):56-66. [pmid: 14700714].
59 Zahedi F. The analytic hierarchy process-a survey of the method and its applications. Interfaces. 1986;16(4):96-108.
60 Fagerlin A, Rovner D, Stableford S, Jentoft C, Wei JT, Holmes-Rovner M. Patient education materials about the treatment of early-stage prostate cancer: a critical review. Ann Intern Med. 2004;140(9):721-8. [pmid: 15126256].
61 Fagerlin A, Zikmund-Fisher BJ, Ubel PA. Helping patients decide: ten steps to better risk communication. J Natl Cancer Inst. 2011;103(19):1436-43. [pmid: 21931068].
62 Chewning B, Bylund CL, Shah B, Arora NK, Gueguen JA, Makoul G. Patient preferences for shared decisions: a systematic review. Patient Educ Couns. 2012;86(1):9-18. [pmid: 21474265].
63 Dwamena F, Holmes-Rovner M, Gaulden CM, et al. Interventions for providers to promote a patient-centred approach in clinical consultations. Cochrane Database Syst Rev. Dec. 12. 2012;12. CD003267.
64 Durand MA, Carpenter L, Dolan H, et al. Do interventions designed to support shared decision-making reduce health inequalities? A systematic review and meta-analysis. PLoS One. 2014;9(4):e94670. [pmid: 24736389].
65 Elwyn G, Scholl I, Tietbohl C, et al. “Many miles to go …”: a systematic review of the implementation of patient decision support interventions into routine clinical practice. BMC Med Inform Decis Mak. Suppl 2. 2013;13:S14. [pmid: 24625083].
66 Evans R, Edwards A, Brett J, et al. Reduction in uptake of PSA tests following decision aids: systematic review of current aids and their evaluations. Patient Educ Counsel. 2005;58:13-26.
67 Gravel K, Légaré F, Graham ID. Barriers and facilitators to implementing shared decision-making in clinical practice: a systematic review of health professionals' perceptions. Implement Sci. 2006;1:16. [pmid: 16899124].
68 Jimbo M, Rana GK, Hawley S, et al. What is lacking in current decision aids on cancer screening?. CA Cancer J Clin. 2013;63(3):193-214. [pmid: 23504675].
69 Joosten EA, DeFuentes-Merillas L, de Weert GH, Sensky T, van der Staak CP, de Jong CA. Systematic review of the effects of shared decision-making on patient satisfaction, treatment adherence and health status. Psychother Psychosom. 2008;77(4):219-26. [pmid: 18418028].
70 Légaré F, Turcotte S, Stacey D, Ratté S, Kryworuchko J, Graham ID. Patients' perceptions of sharing in decisions: a systematic review of interventions to enhance shared decision making in routine clinical practice. Patient. 2012;5(1):1-19. [pmid: 22276987].
71 O'Brien MA, Whelan TJ, Villasis-Keever M, et al. Are cancer-related decision aids effective? A systematic review and meta-analysis. J Clin Oncol. 2009;27(6):974-85. [pmid: 19124808].
72 O'Connor AM, Bennett C, Stacey D, et al. Do patient decision aids meet effectiveness criteria of the international patient decision aid standards collaboration? A systematic review and meta-analysis. Med Decis Making. 2007;27(5):554-74. [pmid: 17873255].
73 Stacey D, Samant R, Bennett C. Decision making in oncology: a review of patient decision aids to support patient participation. CA Cancer J Clin. 2008;58(5):293-304. [pmid: 18755939].
74 Volk RJ, Hawley ST, Kneuper S, et al. Trials of decision aids for prostate cancer screening: a systematic review. Am J Prev Med. 2007;33(5):428-434. [pmid: 17950409].
75 Schonberg MA, Hamel MB, Davis RB, et al. Development and evaluation of a decision aid on mammography screening for women 75 and older. JAMA Intern Med. 2014;174(3):417-24. [pmid: 24378846].
76 LeBlanc A, Kenny DA, O'Connor AM, Légaré F. Decisional conflict in patients and their physicians: a dyadic approach to shared decision making. Med Decis Making. 2009;29(1):61-8. [pmid: 19196706].
77 Elwyn G, Tsulukidze M, Edwards A, Légaré F, Newcombe R. Using a ‘talk’ model of shared decision making to propose an observation-based measure: Observer OPTION 5 Item. Patient Educ Couns. 2013;93(2):265-71. [pmid: 24029581].
78 Wunderlich T, Cooper G, Divine G, et al. Inconsistencies in patient perceptions and observer ratings of shared decision making: the case of colorectal cancer screening. Patient Educ Couns. 2010;80(3):358-63. [pmid: 20667678].