# METHODS

## TOPIC DEVELOPMENT

This topic was nominated by Linda Kinsinger, MD, MPH, VA Chief Consultant for Preventive Medicine at the VA National Center for Health Promotion and Disease Prevention (NCP). The evidence review is intended to examine the effects of SDM interventions for cancer screening practices and to inform what types of interventions NCP will disseminate with their cancer screening guidelines.

## SEARCH STRATEGY

We searched MEDLINE (Ovid), CINAHL, and PsycINFO for randomized controlled trials (RCTs) and systematic reviews published from January 1995 to July 2014 using standard search terms. We limited the searches to articles involving adults and published in the English language. Search terms included terms for cancer screening, and breast, cervical, colorectal, lung, and prostate cancer, and the following SDM terms: decision making; shared decision making; decision aid; informed decision making; values clarification; patient participation; directive counseling; and decision support. The search strategies are presented in detail in Appendix A.

We obtained additional articles from systematic reviews, including a recent Cochrane review of Decision Aids,14 reference lists of included and excluded studies, and suggestions from members of our technical expert panel. We also searched tables of contents from 12 key journals identified by the study investigators and peer reviewers: American Journal of Preventive Medicine; The Annals of Family Medicine; Annals of Internal Medicine; BMC Medical Informatics & Decision Making; British Medical Journal; Cancer Epidemiology, Biomarkers & Prevention; Health Affairs; Health Expectations; Journal of General Internal Medicine; Journal of Medical Screening; Medical Decision Making; and Patient Education & Counseling.

## STUDY SELECTION

Abstracts from the MEDLINE search (n=1640) were reviewed in duplicate, independently by investigators and co-investigators. Abstracts from the CINAHL (n=460) and PsycINFO (n=268) searches were reviewed by a co-investigator. Each article identified for full-text review was independently reviewed by 2 investigators or co-investigators.

We included RCTs comparing a SDM intervention to usual care (UC), alternative SDM interventions, or a combination. We included studies that evaluated SDM interventions for cancer screening as part of the study, excluding studies in which participants made hypothetical cancer screening choices. We included studies involving adults in a clinic setting, either at or shortly before an appointment, as a component to encourage SDM with the clinician. To ensure that we did not include interventions that encouraged screening, we excluded studies that measured only Decision Action (not Decision Quality or Decision Impact) and studies evaluating interventions with the stated goal of promoting screening. Excluded articles are presented in Appendix B.

## DATA ABSTRACTION

Study characteristics (population; sample age, gender, and race; study setting; length of follow-up), SDM intervention characteristics (format, delivery mode, delivery timing/location, inclusion of values clarification exercise, risk communication method, consideration of vulnerable populations, resources required), and outcomes (Decision Quality, Decision Impact, and Decision Action) were extracted onto evidence tables by one investigator or co-investigator and verified by a second.

## QUALITY ASSESSMENT

Individual randomized studies were rated as low, moderate, or high risk of bias based on the following criteria: allocation sequence generation, allocation concealment, blinding, incomplete outcome data, and selective outcome reporting – a modification of the Cochrane approach to determining risk of bias.15

## DATA SYNTHESIS

We organized evidence tables by cancer type and outcome. We critically analyzed studies to compare their characteristics, methods, and findings and compiled a summary of findings for each key question. Due to heterogeneity of the SDM interventions, outcome measures, and timing of outcomes assessment, few data could be pooled, and therefore conclusions are largely based on qualitative synthesis of the findings. To facilitate comparisons across studies, standard mean differences (for continuous outcomes) and risk ratios (for categorical outcomes) were calculated using Review Manager 5.2.^16^ Where pooling was possible, statistical heterogeneity was summarized using the I^2^ statistic (50 percent indicates moderate heterogeneity and 75 percent or greater indicates substantial heterogeneity).17

## RATING THE BODY OF EVIDENCE

We assessed the overall strength of evidence for the outcomes of Decision Quality, Decision Impact, and Decision Action using the method reported by Owens et al.18 One co-investigator with methodology training evaluated strength of evidence and the findings were verified by a second trained co-investigator. The overall evidence was rated as: (1) high, meaning high confidence that the evidence reflects the true effect; (2) moderate, indicating moderate confidence that further research may change our confidence in the estimate of effect and may change the estimate; (3) low, meaning there is low confidence that the evidence reflects the true effect; or (4) insufficient, indicating that evidence either is unavailable or does not permit a conclusion.

## PEER REVIEW

A draft version of this report was reviewed by clinical content experts as well as clinical leadership. Their comments and our responses are presented in Appendix C and the report was modified as needed.