# INTRODUCTION

## BACKGROUND

Decisions about cancer screening have become increasingly complex. Patients must decide whether to get screened, which screening modality to use, and how often to undergo and when to stop screening. Many cancer screening decisions are increasingly recognized as “preference sensitive,” meaning that due to closely-balanced benefits and harms, the “right” decision is in part dependent on an individual's values and preferences for particular outcomes. Most organizations publishing clinical practice guidelines for cancer screening now recommend that preference sensitive cancer screening decisions be made individually, using a process that considers the available evidence on the benefits and harms of particular options, and incorporates patient values and preferences relevant to those options. This approach is sometimes referred to as shared decision making (SDM). The goal of SDM interventions is to facilitate this approach. Adjuncts for the usual counseling for specific decisions, SDM interventions may include: (1) tools to help patients comprehend information about the risks and benefits of options, clarify their personal values related to these options, and participate in decisions consistent with these values and preferences (sometimes referred to as “decision aids”) and (2) other interventions to prepare health care providers and/or systems to support this process. They differ from many health-related interventions in that they primarily seek to elicit and support patient values and preferences in making health care-related decisions rather than to promote a particular health care strategy, per se.

### Addressing Cancer Screening Decisions through SDM - Screening Use

SDM can aid patients in the decision whether or not to be screened. For example, some cancer screening tests have been shown to reduce mortality and provide benefits that exceed harms (net benefit) at a population level. However, for some patient subgroups (eg, older or younger) they may have fewer benefits and more harms than a core group. Screening mammography reduces breast cancer mortality by 32% in relative terms for women in their 60s and 15% for women in their 50s.1 The absolute risk reduction is reflected in the number needed to screen to prevent one cancer death at 10-15 years (approximately 1300 for women in their 50s versus 600 in their 60s).2 Because breast cancer mortality reductions due to screening clearly outweigh the harms, mammography is recommended for these age groups. In contrast, for women younger or older than these age groups or for women with less than a 10-year life expectancy, evidence indicates that screening benefits are reduced while harms (mostly false positive mammograms, breast biopsies and overdiagnosed and overtreated breast cancers) are increased.1 Thus the net benefit becomes smaller and the decision to undergo screening is a “close call” that primarily is determined by patient values and preferences for various known outcomes. Furthermore, at a certain point the benefits do not exceed harms. Thus patients are faced with a decision whether to undergo screening, when to begin, and when to stop screening.3 Other cancer screening tests have less evidence of effectiveness and greater evidence of harm. Screening for prostate cancer with the Prostate Specific Antigen (PSA) blood test is one example. Prostate cancer is the most commonly diagnosed cancer in men, and screening with the PSA test is common. However, randomized screening trials demonstrate that any reduction in prostate cancer mortality through 10-14 years due to PSA screening is at most small (less than 1 in 1000 men screened) and results in harms due to diagnostic testing, overdiagnosis, and overtreatment.4,5 United States Preventive Services Task Force (USPTF) guidelines recommend against PSA screening, concluding that the benefits do not exceed the harms, but suggest that men should not be screened without balanced information about the benefits and harms of PSA screening, and they should make an informed decision that reflects their values and preferences.6

### Addressing Cancer Screening Decisions through SDM – Screening Modality

For some cancers, multiple effective cancer screening modalities exist with no convincing evidence that one approach is superior to another. Therefore an individual has a choice of different screening options. Colorectal cancer screening is effective and suggested for average-risk individuals starting at age 50.^7^ However, colorectal cancer screening has multiple modalities (fecal occult blood testing [FOBT], colonoscopy, sigmoidoscopy). The harms and benefits associated with each of these tests vary.8 Individual patient values and preferences can guide decision making in determining which test is right for the patient. Similarly, cervical cancer screening is recommended; the benefits of such screening exceed the harms for women aged 30-65, when the screening decision primarily involves choosing a screening modality (cytological testing every 3 years or cytological testing plus human papillomavirus testing every 5 years).9

## SHARED DECISION MAKING INTERVENTIONS

Shared decision making (SDM) has been defined as “an approach where clinicians and patients share the best available evidence when faced with the task of making decisions, and where patients are supported to consider options, to achieve informed preferences”.10 SDM interventions are programs designed to facilitate this process. The most commonly implemented and evaluated SDM interventions are decision aids (DAs), defined by the International Patient Decision Aids Standards (IPDAS) collaboration as “tools designed to help people participate in decision making about 2 or more health care options” by providing information about the options and helping patients clarify and communicate the personal values they associate with different features of the options.11 However, SDM interventions may also include provider-directed strategies to enhance SDM receptivity and skills, and system-level modification to provide incentives and resources to facilitate patient and provider-directed strategies.12

Because the goal of SDM is to facilitate the decision making process rather than to promote a particular decision action, effective assessment of the clinical value of SDM must separate the decision making process from the outcome. Therefore, we used a framework that makes this distinction (the Ottawa Decision Support Framework (ODSF)13 to guide our review. The ODSF is an evidence-based theory that separates the decision making process into 3 constructs: Decision Quality, Decision Impact, and Decision Action. The ideal SDM intervention would enhance Decision Quality (ie, increase knowledge and values clarity) and Impact (ie, increase satisfaction, reduce decision conflict, and have minimal impact on service utilization). The desired impact on Decision Action depends on the decision being made. For decisions about how to screen (such as colorectal cancer screening), the ideal SDM intervention would exert the desired effects on Decision Quality and Impact without reducing measures of Decision Action such as screening intention and behavior. For decisions about whether to screen (such as breast, cervical, and prostate cancer in some age groups and risk categories), the goal is to facilitate personalized decision making based on values and preferences. Hence, there are no desired effects on Decision Action per se in this context.

In accordance with the ODSF, we focused on evaluations of SDM interventions that measured the decision making process, and that did not promote a specific screening outcome. Therefore, we excluded interventions that measured only Decision Action outcomes (ie, screening intention and/or screening behavior), even if the authors referred to the intervention as a SDM intervention or as a DA. Additionally, we included any SDM interventions that assessed Decision Quality or Impact in our review, which means that not all included SDM interventions involved the use of DAs as defined by IPDAS.

## OBJECTIVES

The purpose of this review is to examine the effects of SDM interventions for cancer screening in adults on Decision Quality and Impact. For studies reporting Decision Quality or Impact, we also reported Decision Action. We conducted a systematic review of published randomized controlled trials (RCTs) evaluating SDM interventions for cancer screening.

To enhance applicability to current cancer screening evidence and recommendations, we targeted our review to studies published after 1995. We included only studies involving subjects over age 18, as no cancer screening is recommended nor is there an indication for SDM in individuals younger than age 18. Our analytic framework, shown in Figure 1, outlines our PICOS: Population (adults), Interventions (SDM cancer screening interventions), Comparators (usual care, alternative SDM approaches or a combination of both), Outcomes (Decision Quality, Decision Impact, Decision Action, Receptivity, Resources), and Setting (clinic).

Figure 1 Analytic Framework

Our key questions were:

KQ1 In adults, what are the effects of SDM interventions for cancer screening on:
  1. Decision Quality;
  2. Decision Impact; and
  3. Decision Action?
KQ1a Are there differential effects of the interventions based on:
  1. The intervention target (eg, provider-focused, patient-focused, system/organizational focused, multi-level);
  2. Key content/elements of the intervention (eg, format, values clarification exercise, risk communication method);
  3. Patient characteristics (eg, race, gender, age, health literacy); and
  4. Cancer type (eg, breast, cervical, colorectal, prostate, lung)?
KQ2 Within the included studies, what is the receptivity to SDM interventions for cancer screening for:
  1. Patients and
  2. Providers?
KQ3 Within the included studies, what are the resources required to implement a SDM intervention for cancer screening?