# FOREST PLOTS FOR STRENGTH OF EVIDENCE ANALYSIS

## COLORECTAL CANCER

1 Knowledge

Knowledge: CRC Risk Factorsa,b,c

^a^ Range 0-None Correct to 12-All Correct)

^b^ First two comparisons versus control

^c^ Schroy 2012^23^

Adequate Knowledgea

^a^ Trevena 2008^24^

2 Patient's Role in Decision

Perception of How Screening Decisions Were Madea

^a^ Dolan 2002^21^

3 Decisional Conflict

Decisional Conflict Scale (Lower Score = Better Decision Making Process)a,b

^a^ Note: scores reversed from how reported in paper so effect size is now a negative number)

^b^ Dolan 2002

4 Decision Satisfaction

Satisfaction with the Decision-Making Process Scale (SDMP)a,b,c

^a^ 12 items, each scored from 1 (strongly disagree or “poor”) to 5 (strongly agree or “excellent”) with a maximum score of 60

^b^ First two comparisons versus control

^c^ Schroy 2012^23^

5 Screening Intention

Intention to Complete Screening Testa,b,c

^a^ 5 point scale (1 not sure to 5 completely sure)

^b^ First two comparisons versus control

^c^ Schroy 2012^23^

Screening Intentiona

^a^ Trevena 2008^24^

Intention to Screena

^a^ Dolan 2002^21^

6 Screening Behavior

Test Completed by 12 Months after Visita,b

^a^ First two comparisons versus control

^b^ Schroy 2012^23^

Screening Completeda

^a^ Dolan 2002^21^

## PROSTATE CANCER

1 Knowledgea,b

^a^ Multi-armed trials

^b^ Frosch 2008,^28^ Gattellari 2003,^29^ Partin 2004,^35^ Schapira 2000,^37^ Taylor 2013,^39^ Myers 2011^34^

2 Patient's Role in the Decision - Usual Care Trialsa

^a^ Krist 2007,^32^ Partin 2004,^35^ Davison 1999,^25^ Sheridan 2012,^38^ Lepore 2012,^33^ Kripalani 2007^31^

3 Value's Claritya

^a^ Watson 2006^43^

4 Decision Conflict - Usual Care Trialsa

^a^ Gattellari 2003,^29^ Taylor 2013,^39^ Myers 2011,^34^ Volk 2008,^42^ Lepore 2012^33^

5 Decision Satisfactiona

^a^ Percentage reporting high satisfaction, Taylor 2013^39^

6 Screening Preference/Intention - Usual Care Trialsa

^a^ Evans 2010,^26^ Gattellari 2003,^29^ Partin 2004,^35^ Volk 1999,^40^ Watson 2006^43^

^b^ Includes Evans and Partin studies with significant or more significant results. ^c^ Includes Evans and Partin studies with non-significant or less significant results.

7 Screening Preference/Intention - Other Trialsa

^a^ Lepore 2012,^33^ Sheridan 2012,^38^ Evans 2010^26^

8 Screening Outcomes - Usual Care Trialsa

^a^ Schapira 2000,^37^ Partin 2004,^35^ Taylor 2013,^39^ Volk 1999,^40^ Kripalani 2007^31^

9 Screening Outcomes - Other Trialsa

^a^ Krist 2007,^32^ Evans 2010,^26^ Myers 2011,^34^ Lepore 2012,^33^ Sheridan 2012^38^