# STRENGTH OF EVIDENCE

Outcome Category | Outcome (# of Studies Reporting) | Results Shared Decision Making vs Control | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Breast Cancer (k=2)
Decision Quality Overall Strength of Evidence: Low | Knowledge (2) | 77% (Intervention) vs 57% (Control); P = .02 (Mathieu 2007)19 94% (Intervention) vs 83% (Control); P < .001 (Mathieu 2010)20 | Moderate (2) | Consistent (based on direction) | Direct | Precise (based on p-values) | Moderate
Decision Quality Overall Strength of Evidence: Low | Values Clarity (2) | Means: 19.5 (Intervention) vs 22.6 (Control); P = .02 (Mathieu 2007)19 Positive values: 79% (Intervention) vs 79% (Control); p=ns (Mathieu 2010)20 | Moderate (2) | Inconsistent | Direct | Imprecise | Low
Decision Quality Overall Strength of Evidence: Low | Patient's Role in Decision (0) | | | | | | Insufficient
Decision Impact Overall Strength of Evidence: Insufficient | Decisional Conflict (1) | Means: 20.1 (Intervention) vs 21.9 (Control); P= .12 (Mathieu 2007)19 | Moderate | NA | Direct | Unclear | Low
Decision Impact Overall Strength of Evidence: Insufficient | Use of Services (0) | | | | | | Insufficient
Decision Impact Overall Strength of Evidence: Insufficient | Decision Satisfaction (0) | | | | | | Insufficient
Decision Action Overall Strength of Evidence: Low | Screening Intention (2) | OR=1.28 [0.63, 2.61]; P = .50 (Mathieu 2007)19 Intention to Screen: 52% (Intervention) vs 65% (Control); P = .05 (Mathieu 2010)20 | Moderate (2) | Inconsistent | Direct | Imprecise | Low
Decision Action Overall Strength of Evidence: Low | Screening Behavior (1) | Screened: 6% (Intervention) vs 7% (Control); p=ns (Mathieu 2007)19 | Moderate | NA | Direct | Unclear | Low
Colorectal Cancer (k=3)
Decision Quality Overall Strength of Evidence: Low | Knowledge (2) | DA:SMD=1.06 [0.88, 1.24] (Schroy 2012)23 DA+YDR: SMD=0.92 [ 0.75, 1.10] (Schroy 2012)23 RR 3.58 [ 1.69, 7.57] (Trevena 2008)24 | Moderate (2) | Consistent (based on direction) | Direct | Precise | Moderate
Decision Quality Overall Strength of Evidence: Low | Values Clarity (1) | 62% vs 59%, P = .63 (Trevena 2008)24 | Moderate | NA | Direct | Unclear | Low
Decision Quality Overall Strength of Evidence: Low | Patient's Role in Decision (1) | Perception of how screening decision were made: Shared: RR=1.23 [0.85, 1.78] (Schroy 2012)23 Physician: RR=1.17 [0.43. 3.19] (Schroy 2012)23 Patient: RR 0.60 [0.29, 1.22] (Schroy 2012)23 | Moderate | NA | Direct | Imprecise | Low
Decision Impact Overall Strength of Evidence: Low | Decisional Conflict (1) | SMD=-0.29 [-0.74, 0.15](Dolan 2002)21 | Moderate | NA | Direct | Imprecise | Low
Decision Impact Overall Strength of Evidence: Low | Use of Services (0) | | | | | | Insufficient
Decision Impact Overall Strength of Evidence: Low | Decision Satisfaction (1) | DA: SMD=0.59 [0.41, 0.78] (Schroy 2012)23 DA+YDR: SMD=0.50 [0.32, 0.67] (Schroy 2012)23 | Moderate | NA | Direct | Precise | Low
Decision Action Overall Strength of Evidence: Low | Screening Intention (3) | RR=0.48 [0.23, 1.00] (Dolan 2010)21 DA:SMD=0.30 [0.11, 0.49] (Schroy 2012)23 DA+YDR: SMD=0.40 [0.21, 0.59] (Schroy 2012)23 RR=0.96 [0.89, 1.05] (Trevena 2008)24 | Moderate (3) | Inconsistent | Direct | Imprecise | Low
Decision Action Overall Strength of Evidence: Low | Screening Behavior (3) | RR=0.94 [0.57, 1.53] (Dolan 2012)21 DA: RR=1.24 [1.00, 1.53] (Schroy 2012)23 DA+YDR: RR=1.07 [0.86, 1.33] (Schroy 2012)23 Completed FOBT: 5.2% (Intervention) vs 6.6% (Control); P = .64 (Trevena 2008)24 | Moderate (3) | Inconsistent | Direct | Imprecise | Low
Prostate Cancer (k=18)
Decision Quality Overall Strength of Evidence: Moderate | Knowledge (12) Did not include Gattellari 2205 (MDs) Volk 2008 (No data – reported improved knowledge with no difference between 2 decision aids) Frosch 2003 (Comparison of 2 DAs with greater knowledge in video DA group) | SMD=0.29 [0.02, 0.56] (Gattellari 2003)29 SMD=0.36 [0.11, 0.60] (Schapira 2000)37 48% vs, 31%; P < .001 (Volk 1999/2003)40,41 Median difference 4.0 [4.0, 5.0] (Watson 2006)43 Means: 4.90 (Prosdex) vs 5.40 (Paper version) vs 2.17 (Control); P < .001 for Prosdex vs Control (Evans 2010)26 SMD=0.46 [0.23, 0.69] (Internet vs Control) (Frosch 2008)28 SMD=0.26 [0.03, 0.48] (CDTM vs Control) (Frosch 2008)28 Means: 69% (Internet) vs 69% (Brochure), 54% (Control); both P < .001 vs Control (Krist 2007)32 SMD=0.44 [0.20, 0.67] (Myers 2011)34 SMD=0.24 [0.10, 0.38] (Video vs UC) (Partin 2004)35 SMD=0.18 [0.03, 0.32] (Pamphlet vs UC) (Partin 2004)35 61.6 (Intervention) vs 54.7 (Control); P < .001 (Lepore 2012)33 AD=34% [19, 50] (Sheridan 2012)38 SMD=0.54 [0.42, 0.66] (Taylor 2013 Print)39 SMD=0.50 [0.38, 0.62] (Taylor 2013 Web)39 | Moderate (11) Low(1) | Generally Consistent (based on direction) | Direct | Generally Precise | Moderate
Decision Quality Overall Strength of Evidence: Moderate | Values Clarity (4) | 1.7 (Intervention) vs 1.4 (Control); P = .056 (Gattellari 2003)29 -3.5 (Intervention) vs +3.3 (Control) ( P < .0001); SMD==0.37 [-0.50,-0.24] (Watson 2006)43 Means: 32.3 (Traditional DA) vs 36.6 (CDTM) vs 37.9 (Control); P < .05 TDA vs others (Frosch 2008)28 RR=2.79 [1.96, 3.47] (Sheridan 2012)38 | Moderate (4) | Inconsistent | Direct | Imprecise | Low
Decision Quality Overall Strength of Evidence: Moderate | Patient's Role in Decision (7) Did not include Gattellari 2005 (MDs) Volk 2008 (Comparison of 2 DAs with no significant difference) Watson 2006 (Baseline only) | RR=1.28 [1.03, 1.59] (Partin 2004, Pamphlet)35 RR=1.09 [0.87, 1.37] (Partin 2004, Video)35 RR=1.55 [1.11,2.17] (Kripalani 2007 Cue)31 RR=1.34 [0.94,1.90] (Kripalani 2007 Patient Ed)31 RR=1.22 [0.91, 1.63] (Krist 2007 Active Internet vs UC)32 RR=1.17 [0.87, 1.58] (Krist 2007 Active Brochure vs UC)32 Means: 11.4 (MD-Ed) vs 12.3 (MD-Ed+A)vs 11.8 (UC); p=ns (interventions vs control) (Wilkes 2013)44 RR=2.82 [1.60, 4.96] (Davison 1999 Active)25 RR=0.90 [1.11, 3.25] (Lepore 2012)33 RR=0.96 [0.76, 1.23] (Sheridan 2012)38 | Moderate (6) Low(1) | Inconsistent | Direct | Imprecise | Low
Decision Impact Overall Strength of Evidence: Low | Decisional Conflict (8) Did not include Volk 2008 (Comparison of 2 DAs with significant difference at low literacy site) Gattellari 2005 (MDs) | SMD=0.00 [-0.27, 0.27] (Gattellari 2003)29 Means: 40.4 (Prosdex) vs 38.5 (Paper version) vs 47.7 (Control); P < .001 (Prosdex vs Control) (Evans 2010)26 Mean of Reported DCS subscale scores: 28.7 (I1) vs 32.5 (I2) vs 34.3 (UC); P < .05 for I1 vs Control (Frosch 2008)28 Means: 1.6 (Internet) vs 1.5 (Brochure) vs 1.6 (UC); p=ns (Krist 2007)32 SMD=-0.07 [-0.30, 0.16] (Myers 2011)34 Means: 28.5 (Intervention) vs 35.2 (Control); P < .0001 (Davison 1999)25 SMD=-0.24 [-0.43, -0.05] (Lepore 2012)33 SMD=-0.22 [-0.34, -0.10] (Taylor 2013 Print)39 SMD=-0.18 [-0.30, -0.05] (Taylor 2013 Web)39 | Moderate (7) Low(1) | Inconsistent | Direct | Imprecise | Low
Decision Impact Overall Strength of Evidence: Low | Use of Services (1) | Means: 5.1 (Internet) vs 5.3 (Brochure) vs 5.2 (UC); p=ns (Krist 2007)32 | Moderate (1) | NA | Direct | Precise | Low
Decision Impact Overall Strength of Evidence: Low | Decision Satisfaction (2) | Means: 24.3 (Intervention) vs 23.8 (Control); p=ns (Volk 1999/2003)40,41 RR=1.12 [0.99, 1.26] (Taylor 2012 Print)39 RR=1.01 [0.89, 1.15] (Taylor 2012 Web)39 | Moderate (1) Low(1) | Consistent | Direct | Precise | Low
Decision Action Overall Strength of Evidence: Low | Screening Intention (7) Did not include Gattellari 2005 (MDs) | RR=1.02 [0.88, 1.18] (Gattellari 2003)29 RR=0.77 [0.63, 0.95] (Volk 1999)40 RR=0.88 [0.72, 1.08] (Watson 2006)43 Means: 40% (Prosdex) vs 53% (Paper) vs 58% (Control); P = .02 (Prosdex vs Control) (Evans 2010)26 RR=0.69 [0.51, 0.94] (Evans 2010 Prosdex vs Control)26 RR=0.90 [0.69, 1.18] (Evans 2010 Paper vs Control)26 RR=0.85 [0.76, 0.95] (Video vs UC) (Partin 2004)35 RR=0.89 [0.80, 0.99] (Pamphlet vs UC) (Partin 2004)35 RR=1.00 [0.91, 1.09] (Lepore 2012)33 RR=0.57 [0.42, 0.78] (Sheridan 2012)38 | Moderate (7) | Inconsistent | Direct | Generally Precise | Low
Decision Action Overall Strength of Evidence: Low | Screening Behavior (10) Did not include Davison 1999 (No statistical test of results possible) Frosch 2003 (Comparison of 2 DAs with significantly fewer PSAs in video group) Frosch 2008 (Reduction in PSA pre to post) Wilkes 2013 (Overall PSA ordering; no data for groups) Gattellari 2005 (MDs) | RR=0.98 [0.88, 1.09] (PSA+DRE) (Schapira 2000)37 RR=0.62 [0.42, 0.92] (PSA) (Volk 1999)40 RR=0.96 [0.62, 1.47] (DRE) (Volk 1999)40 Means: 3% (Prosdex) vs 9% (Paper) vs 9% (Control); P = .014 (Prosdex vs Control) (Evans 2010)26 RR=0.35 [0.12, 1.08] (Evans 2012 Prosdex vs Control)26 RR=1.02 [0.46, 2.26] (Evans 2012 Paper vs Control)26 RR=0.91 [0.84, 0.99] (Internet vs UC) (Krist 2007)32 RR=0.90 [0.83, 0.98] (Brochure vs UC) (Krist 2007)32 RR=5.12 [1.18, 22.67] (Kripalani 2007 PSA Cue vs UC)31 RR=5.86 [1.35, 25.38] (Kripalani 2007 PSA Patient Ed vs UC)31 RR=1.02 [0.31, 3.41] (Kripalani 2007 DRE Cue vs UC)31 RR=0.78 [0.22, 2.81] (Kripalani 2007 DRE Patient Ed vs UC)31 RR=0.88 [0.75, 1.04] (Myers 2011)34 RR=0.96 [0.86, 1.07] (Video vs UC) (Partin 2004)35 RR=0.96 [0.86, 1.07] (Pamphlet vs UC) (Partin 2004)35 RR=0.94 [0.82, 1.08] (Lepore 2012)33 RR=0.46 [0.25, 0.83] (Sheridan 2012)38 RR=1.01 [0.91, 1.13] (Taylor 2012 Print)39 RR=0.97 [0.86, 1.08] (Taylor 2012 Web)39 | Moderate (8) Low (2) | Inconsistent | Direct | Generally Precise | Low

k = number of studies; ns = not statistically significant; SMD = standard mean difference; RR = risk ratio; AD = absolute difference; UC = usual care; DA = decision aid; YDR = “Your Disease Risk”; CDTM = Chronic Disease Trajectory Model; MD-Ed = Physicians participated in Web-based educational program ; MD-Ed+A = Physician Web-based educational program plus activated patients (patients who viewed different but related educational program); C1 = control with survey; I1 = traditional decision aid; I2 = chronic disease trajectory model

a Standard mean differences and risk ratios were calculated for inclusion on the strength of evidence table if authors provided data necessary for these calculations.