# DECISION QUALITY AND DECISION IMPACT MEASURE PATTERNS IN INCLUDED STUDIES

Measure | Measure Description | SDM Intervention ↑ | No Intervention Effect | SDM Intervention ↓
Decision Quality
Knowledge
Investigator-developed measure | (number of items) | Evans 2010 (12)26 Frosch 2003 (5)28 Gattellari 2005 (7)29 Lepore 2012 (14)33 Mathieu 2007 (10)19 Mathieu 2010 (10)20 Myers 2011 (10)34 Schapira 2000 (18)37 Schroy 2011/2012 (12)22,23 Taylor 2013 (18)39 Trevena 2008 (10)24 Watson 2006 (18)43
Previously validated index (Radosevich 2004)46 | 10 items; sum of correct responses | Frosch 2008^28^ Partin 2004/2006^35,36^ Sheridan 2012 (4 items)38
PC-Know (O'Dell 1999);47 developed for Volk 1999/2003^40,41^ | 10 items; scored % of correct answers | Krist 2007^32^ Gattellari 2003^29^ Volk 1999/2003^40,41^ | Volk 2008^42^
Values Clarity
Decision Conflict Scale: Values Subscale (O'Connor 1995)54 | 0-100; values considered “clear” if score is ≤ 25 | Frosch 2008^28^ | Trevena 2008^24^ | Mathieu 2007^19^
Decisional Balance Score (created by authors) | 12 items; Summary measure | Watson 2006^43^
Dormandy Scale (Dormandy 2006)48 | 0-100; score≥ 50 = positive mamm. attitudes, score < 50 = negative mammo. attitudes | | Mathieu 2010^20^
Indecision about screening intention | Made a decision about intention | | | Mathieu 2007^19^ Mathieu 2010^20^
Strength of agreement with PSA, modified from previous attitude measures (Rakowski 1997)49 | range -5 to +5 | | Gattellari 2003^29^
“PSA is a Decision” item (1 of 3) (McCormack 2011)50 | 1 item; 5 responses | Sheridan 2012^38^
Patient's Role in Decision
Control Preferences Scale (CPS) (Degner 1992)51 | 1 item; 5 responses reflecting SDM preference | Davison 1999^25^ Gattellari 2005^30^ Krist 2007^32^ | Sheridan 2012^38^ Watson 2006^43^
Discussed PSA | | Kripalani 2007^31^ Lepore 2012^33^ Partin 2004/2006^35,36^
Modified from Kaplan's SDM instrument (Kaplan 1995)45 | Perception of SDM 4 4-point scales | | Wilkes 2013^44^
Patient Self Advocacy Scale (PSAS) (Brashers 1999)52 | 12 item; 5 point scale | | Volk 2008^42^
Patient perception of how screening decision was made (Strull 1984)53 | 1 item; 5 responses | | Dolan 2002^21^
Decision Impact
Decision Conflict
Decision Conflict Scale (DCS) (O'Connor 1995)54 | 16-item; 0 = no decisional conflict, 100 = extreme decisional conflict | | Krist 2007^32^ Mathieu 2007^19^ Myers 2011^34^ Volk 2008^42,a^ | Davison 1999^25^ Dolan 2002^21^ Evans 2010^26^ Frosch 2008^28^ Gattellari 2003^29^ Lepore 2012^33^ Taylor 2013^39^ Volk 2008^42,a^
Provider Decision Process Assessment Instrument (Dolan 1999)55 | Extent to which GPs experience uncertainty; 9 items (range 9-45) | | | Gattellari 2005^30^
Decision Satisfaction
Satisfaction with the Decision-Making Process Scale (SDMP) (Barry 1997)56 | 12-item; scores range from 5 to 60 | Schroy 2011/2012^22,23^
Satisfaction with Decision (SWD) (Holmes-Rovner 1996)57 | 6-item; 5 point responses | Taylor 2013^39,b^ | Taylor 2013^39,b^ Volk 1999/2003^40,41^
Use of Services
Consultation length | Minutes | | Krist 2007^32^

a High literacy version of DCS no intervention effect; low literacy version of DCS intervention group lower DCS score

b Intervention group had higher SWD scores at time 1 (1 month), but no significant difference at time 2 (13 months)