# EVIDENCE TABLES

## BREAST CANCER

Table 1 Characteristics of Breast Cancer Studies (k=2)

AUTHOR, YEAR (COUNTRY) | SCREENING OPTIONS | INTERVENTION TARGET | INTERVENTION (I) (n) COMPARATOR (C) (n) | SAMPLE CHARACTERISTICS | SETTING | LENGTH OF FOLLOW-UP % WITHDRAWLS | RISK OF BIAS
Mathieu, 2007^19^ (Australia) | Mammography | 70 y/o women in Australia who accessed gov't on line mammography site; 2 screening mammograms in past 5 years; due for next screening within next 3 months; no prior diagnosis of breast cancer | I: Mailed DA(367) C: Standard screening brochure (367) | Age: 70 yrs Race/Ethnicity: NR Previous Screen (%): 100 | Australian population screening program, BreastScreen Australia | Immediately, 1 month 3% did not return questionnaire 3% did not complete follow-up interview | Sequence generation: adequate Allocation concealment: adequate Blinding: telephone follow-up blinded; other data by self-administered questionnaire Incomplete outcome data: 3% no questionnaire; 11%^a^ of questionnaires incomplete; 3% no interview Selective outcome reporting: no Risk of Bias: Moderate
Mathieu, 2010^20^ (Australia) | Mammography | 38-45 y/o women in Australia who accessed gov't web site for mammography; no prior diagnosis of breast cancer | I: Web-based DA (189) C: Survey and delayed DA (223) | Age: 42 yrs Race/Ethnicity: NR Previous Screen (%): 11 | Australian population screening program, BreastScreen Australia | Immediately 19% withdrew or excluded before accessing DA; outcome data for 63% of patients randomized | Sequence generation: adequate Allocation concealment: adequate Blinding: unclear Incomplete outcome data: 37% missing outcome data;61% did not complete informed choice analysis Selective outcome reporting: no Risk of Bias: Moderate

k = number of studies; DA=Decision Aid

a Data analysis included all who completed specific sections of the questionnaire

Table 2 Characteristics of Interventions from Breast Cancer Studies

AUTHOR, YEAR | DELIVERY MODE | DELIVERY TIMING and LOCATION | VALUES CLARIFICATION EXERCISE | RISK COMM. METHOD | CONSIDERED HEALTH LITERACY or NUMERACY | RESOURCES (COST, STAFF, PHYSICAL)
Mathieu, 2007^19^ | Mailed booklet | Home | Worksheet with examples provided | 1000-face pictograms: Event rate per 1000 women screened every 2 years over 10 years, starting at age 70 | Not specified | Unclear
Mathieu, 2010^20^ | Website | Home | Worksheet with examples provided | Diagrams as event rates per 1000 women screened every 2 years over 10 years, and per 1000 women who are not screened over 10 years | Not specified | Unclear

DA=Decision Aid

Table 3 Decision Quality Outcomes Assessed in Breast Cancer Studies

AUTHOR, YEAR | KNOWLEDGE | | PATIENT ROLE IN DECISION | | VALUES CLARITY
AUTHOR, YEAR | Intervention | Control | Intervention | Control | Intervention | Control
Mathieu, 2007^19^ | 76.6% adequate knowledge^a^ Informed choice^b^ 73.5% | 56.9% adequate knowledge χ^2^=31.15, p = .02 Informed choice 48.8%, (χ^2^=37.92; P<.001). | - | - | Clear Values^c^ Mean = 19.51 Decided Undecided: 4.9% Decided: 95.1% | Clear Values Mean = 22.59, T_545_=2.27, p= .02 Decided Undecided: 10.1% Decided: 89.9% OR 0.32 (0.17, 0.63), P < .001
Mathieu, 2010^20^ | Mean 7.35 94% adequate^a^ Informed choice^b^ 71% | Mean 6.27, p<.001 83% adequate, p<.001 Informed choice 64%, p=NS | - | - | Decided Undecided: 18% Intention – Decided: 82% | Decided Undecided: 39% Intention – Decided: 61% χ^2^=15.72, P<0.001

a Adequate knowledge defined as a score of 6/10 or higher

b Participants were classified as having made an informed choice if they had either (1) adequate knowledge, positive values towards screening, and intention to attend screening; or (2) adequate knowledge, negative values towards screening, and intention to decline screening

c Decisional Conflict Scale – Values Subscale: values considered “clear” if score is ≤ 25

Table 4 Decision Impact Outcomes Assessed in Breast Cancer Studies

AUTHOR, YEAR | DECISIONAL CONFLICT | | USE OF HEALTH SERVICES | | DECISION SATISFACTION
AUTHOR, YEAR | Intervention | Control | Intervention | Control | Intervention | Control
Mathieu, 2007^19^ | DCS^a^ Mean =20.06 | DCS Mean =21.89, p= .12 | - | - | - | -
Mathieu, 2010^20^ | - | - | - | - | - | -

a Decisional Conflict Scale – higher scores indicate greater decisional conflict or uncertainty.

Table 5 Decision Action Outcomes Assessed in Breast Cancer Studies

AUTHOR, YEAR | SCREENING INTENTION | | SCREENING BEHAVIOR
AUTHOR, YEAR | Intervention | Control | Intervention | Control
Mathieu, 2007^19^ | Intention – Stop screening: 9.5% Intention –Continue screening: 85.7%^a^ | Intention – Stop screening: 9.3% Intention – Continue screening: 80.6% OR 1.28 (0.63, 2.61), p=.50 | Screened: 5.9% Unscreened, but have made appointment, or planning to make appointment: 75.7% Unscreened: 18.4% | Screened: 7.0% Unscreened, but have made appointment, or planning to make appointment: 74.7% Unscreened : 18.3% P=NS
Mathieu, 2010^20^ | Intention – Screen: 52% Intention – Not screen: 48%^b^ χ^2^=4.00, P = .05 | Intention – Screen: 65% Intention – Not screen: 35% | - | -

a Percent of total group (decided and undecided)

b Percent of women who had made a decision

## COLORECTAL CANCER

Table 6 Characteristics of Colorectal Cancer Studies (k=3)

AUTHOR, YEAR (COUNTRY) | SCREENING OPTIONS | INTERVENTION TARGET | INTERVENTION (I) (n) COMPARATOR (C) (n) | SAMPLE CHARACTERISTICS | SETTING | LENGTH OF FOLLOW-UP % WITHDRAWLS | RISK OF BIAS
Dolan, 2002^21^ (United States) | FOBT, FS, FOBT+FS, BE, COL | Men and women at average risk for CRC; CRC screening eligible | I: Interview plus printed DA (N=49) C: Interview plus printed educational materials (N=46) | Age (yr): 66.1 Gender (Male%): 47.5 Race/Ethnicity (%): white 98 Previously screened (%): 27.3 | 2 Internal Medicine practices | Follow up; 1. Immediate; 2. 2-3 mo. chart review; 1% withdrawals | Sequence generation: Adequate Allocation concealment: Unclear Blinding: Yes (chart review) Incomplete outcome data: No Selective outcome reporting: No Risk of Bias: Moderate
Schroy, 2011^22^ Schroy, 2012^23^ (United States) | FOBT, FS, FOBT+FS, BE, COL | Average risk patient under care of primary care provider at study sites; 50 to 75 years old; no prior CRC screening examinations Excluded: prior CRC screening other than FOBT; high-risk conditions (personal history of CRC or polyps, family history of CRC or polyps, chronic IBD); comorbidities that preclude CRC screening by any method | I1: DA plus “Your Disease Risk” tool (YDR)(n=223) (n=280 for Schroy 2012) I2: DA (n=212) (n=269 for Schroy 2012) C: Control (modified version of “9 Ways to Stay Healthy and Prevent Disease”) (n=231) (n=276 for Schroy 2012) | Schroy 2011 Age (yr): 83% <65 years; 17% 65+ years Gender (Male%): 41 Race/Ethnicity (%): black 62, white 34, Asian 2 Previously screened (%): 14 (FOBT only) Schroy 2012 Age (yr): 84% <65 years; 16% 65+ years Gender (Male%): 41 Race/Ethnicity (%): black 62, white 34, Asian 2 Previously screened (%): 13 (FOBT only) | 2 urban ambulatory care clinics (1 private, academic-affiliated, 1 community clinic affiliated with academic clinic) 50 providers (47 MDs, 3 NPs) participated; pre-study seminars about CRC screening, SDM, overview of study | Schroy 2011 Follow up; 1. Immediate (post-visit); 2. Medical record review for screening test ordered (time of review not reported) % withdrawals not reported; Schroy 2012 Follow up 12 months post-visit 0% withdrawals | Sequence generation: Unclear Allocation concealment: Adequate Blinding: Unclear Incomplete outcome data: No Selective outcome reporting: No Risk of Bias: Moderate
Trevena, 2008^24^ (Australia) | FOBT | Between 50 and 74 years old Excluded: poor English, significant cognitive impairment, serious physical or mental illness, resident of nursing homes, personal history of colorectal cancer; previous FOBT, FS, or COL (past 2 years); strong family history of CRC | I: DA (age, gender, family history specific) (n=157) C: Government consumer guidelines on FOBT (n=157) Both groups received self-administered questionnaire | Age (yr): 50-54 years 23%; 55-64 years 41%; 65-74 years 35% Gender (Male %): 42 Race/Ethnicity (%): NR Previously screened (%): NR | 1 rural and 5 urban family practices | Follow-up: 1 month after mailing 14.3% withdrawals | Sequence generation: Adequate Allocation concealment: Adequate Blinding: Participants were blinded to study hypothesis; researchers were blinded to allocations for telephone interviews (questionnaires were self-administered) Incomplete outcome data: Selective outcome reporting: Risk of Bias: Moderate

k = number of studies; BE = barium enema; COL = colonoscopy; CRC = colorectal cancer; DA = decision aid; FOBT = fecal occult blood test; FS = flexible sigmoidoscopy; IBD = inflammatory bowel disease

Table 7 Characteristics of Interventions from Colorectal Cancer Studies

AUTHOR, YEAR | DELIVERY MODE | DELIVERY TIMING and LOCATION | VALUES CLARIFICATION EXERCISE | RISK COMM. METHOD | CONSIDERED HEALTH LITERACY or NUMERACY | RESOURCES (COST, STAFF, PHYSICAL)
Dolan, 2002^21^ | Counseling and print | Prior to routine appointment | Analytic hierarchy process | Not specified | Not specified | Study team member-administrated intervention prior to appointment
Schroy, 2011^22^ Schroy, 2012^23^ | DVD | 1 hr prior to prearranged office visit with primary care provider Private office | Discrete choice method to identify screening preference | Web-based “Your Disease Risk” (YDR), personalized risk estimates; audio/visual | Conducted focus groups to determine key factors (including literacy) to include in DA; Prototype modified after usability testing | Research assistants administered pre-test, web-based program
Trevena, 2008^24^ | Booklet Question set | Home | Personal worksheet required participants to indicate what was important to them | 1000-face diagrams | Readability score: Grade 10 | Unclear

DA = decision aid

Table 8 Decision Quality Outcomes Assessed in Colorectal Cancer Studies

AUTHOR, YEAR | KNOWLEDGE | | PATIENT'S ROLE IN THE DECISION | | VALUES CLARITY
AUTHOR, YEAR | Intervention | Control | Intervention | Control | Intervention | Control
Dolan, 2002^21^ | - | - | Perception of how screening decisions were made: Primarily MD 7 (16.3%) Shared 27 (62.8%) Primarily patient 9 (20.9%) | Perception of how screening decisions were made: Primarily MD 6 (13.9%) Shared 22 (51.2%) Primarily patient15 (34.9%), P = .35 | - | -
Schroy, 2011^22^ | Baseline DA+YDR: 7.6 (2.8)* DA: 7.7 (2.9)^a^ Post-visit DA+YDR: 10.7 (1.8)* DA: 10.9 (1.6)^a^ EFFECT sizes (vs control) DA+YDR: d=1.15 DA: d=1.27 | Baseline Control: 7.5 (2.7)* Overall P=0.91 Post-visit Control: 8.6 (2.7)* P<0.001 for 2 intervention groups vs control | - | - | - | -
Schroy, 2012^23^ Continuation of Schroy 2011^22^ | Baseline DA+YDR: 7.7 (2.9)* DA: 7.9 (2.8)^a^ Post-visit DA+YDR: 10.7 (1.9)^a^ DA: 10.9 (1.6)* | Baseline Control: 7.5 (2.8)* Overall P=0.36 Post-visit Control: 8.6 (2.6)* P <.001 for 2 intervention groups vs control | - | - | - | -
Trevena, 2008^24^ | Adequate knowledge^b^ 28/134 (20.9%); P= .0001 Integrated knowledge and values‖ 14/134 (10.4%); P= .002 | Adequate knowledge 8/137 (5.8%) Integrated knowledge values‖ 2/137 (1.5%) | - | - | Clear values^c^ 83/134 (62%) | Clear values 81/137 (59%) P= .63

CRC = colorectal cancer; DA = decision aid; DA+YDR = decision aid plus “Your Disease Risk”; MD=physician

a 12 item true/false questionnaire about CRC risk factors, rationale and goals of screening, age at which screening should begin; 0 = no correct responses, 12 = all correct responses

b Adequate knowledge defined as positive scores for understanding the potential benefits and potential arms of screening; integrated knowledge and values defined as clear values and adequate knowledge

c Decisional Conflict Scale – Values Subscale: values considered “clear” if score is ≤ 25

Table 9 Decision Impact Outcomes Assessed in Colorectal Cancer Studies

AUTHOR, YEAR | DECISIONAL CONFLICT^a^ | | USE OF HEALTH SERVICES | | DECISION SATISFACTION
AUTHOR, YEAR | Intervention | Control | Intervention | Control | Intervention | Control
Dolan, 2002^21^ | 1.83 (0.52)^b^ P = .01 effect size=0.29 | 2.03 (0.81) | - | - | - | -
Schroy, 2011^22^ | - | - | - | - | Mean SDMP scores^c^ DA + YDR: 50.5 (6.2), N=214 DA: 50.7 (6.2) N=205 | Mean SDMP scores Control: 46.7 (7.9) N=217 P <.001
Schroy, 2012^23^ Continuation of Schroy, 2011^22^ | - | - | - | - | Mean SDMP scores^c^ DA+YDR: 49.0 (6.2), n=271 DA: 49.7 (6.4), n=262 | Mean SDMP scores †† Control: 45.5 (7.8), n=261; P < .001
Trevena, 2008^24^ | - | - | - | - | - | -

a Scores are means (standard deviation) unless indicated; DA+YDR = decision aid plus “Your Disease Risk”

b Decisional Conflict Scale (low literacy version) - Maximum = 100; 0 = no decisional conflict, 100 = extreme decisional conflict

c 12-item Satisfaction with the Decision-Making Process Scale, each item scored from 1 (strongly disagree or “poor”) to 5 (strongly agree or “excellent”); maximum score = 60

Table 10 Decision Action Outcomes Assessed in Colorectal Cancer Studies

AUTHOR, YEAR | SCREENING INTENTION | | SCREENING BEHAVIOR
AUTHOR, YEAR
AUTHOR, YEAR | Intervention | Control | Intervention | Control
Dolan, 2002^21^ | FOBT 23 (51%) W&S 8 (18%) FOBT+FS 6 (13%) FS 6 (13%) BE 1 (2%) COL 1 (2%) | FOBT 17 (39%) W&S 16 (37%) FOBT+FS 8 (18%) FS 2 (5%) BE 0 COL 0 All P = ns | FOBT 11 (48%) W&S 8 (100%) FOBT+FS 2 (33%) FS 4 (67%) BE 0 COL 1 (100%) | FOBT 6 (35%) W&S 15 (94%) FOBT+FS 7 (88%) FS 1 (50%) BE 0 COL 0
Schroy, 2011^22^ | DA+YDR: COL 132/223 (60%) FOBT 53/223 (24%) FS 13/223 (6%) FOBT+FS 6/223 (2%) BE 8/223 (4%) None 8/223 (4%) DA: COL 120/212 (57%) FOBT 58/212 (28%) FS 11/212 (5%) FOBT+FS 5/212 (3%) BE 9/212 (4%) None 7/212 (3%) P = ns (between groups) | NR | - | -
Schroy, 2011^22^ | Intention to Schedule Screening† DA+YDR: 4.3 (1.0) DA: 4.4 (1.0) | Intention to Schedule Screening† Control: 3.9 (1.4) P < .001 vs 2 intervention groups | - | -
Schroy, 2011^22^ | Intention to Complete Screening Test† DA+YDR: 4.3 (1.0) DA: 4.3 (1.0) EFFECT sizes: Ranged from 0.36 to 0.44 for intention to schedule or complete for 2 intervention groups vs control | Intention to Complete Screening Test† Control: 3.9 (1.3) P < .001 vs 2 intervention groups | - | -
Schroy, 2012^23^ Continuation of Schroy 2011^22^ N=825 | Intention to Schedule Screening^a^ DA+YDR: 4.3 (1.0) (n=280) DA: 4.4 (1.0) (n=269) | Intention to Schedule Screening Control: 3.9 (1.3) (n=276) P < .001 vs 2 intervention groups | Test Completed by 12 Months After Visit DA+YDR: 37.1% OR 1.03 (0.72, 1.48) vs control DA: 43.1% OR 1.30 (0.90, 1.87) vs control DA+YDR vs DA, P = .153 | Test Completed by 12 Months After Visit Control: 34.8%, P = .046 vs DA
Schroy, 2012^23^ Continuation of Schroy 2011^22^ N=825 | Intention to Complete Screening Test^a^ DA+YDR: 4.4 (1.0) (n=280) DA: 4.3 (1.0) (n=269) Test Ordered by 12 months After Vsit DA+YDR: 73.6% DA: 80.7% DA+YDR vs DA: P = .048 | Intention to Complete Screening Test Control: 4.0 (1.3) (n=269) P < .001 vs 2 intervention groups | Test Completed by 12 Months After Visit DA+YDR: 37.1% OR 1.03 (0.72, 1.48) vs control DA: 43.1% OR 1.30 (0.90, 1.87) vs control DA+YDR vs DA, P = .153 | Test Completed by 12 Months After Visit Control: 34.8%, P = .046 vs DA
Schroy, 2012^23^ Continuation of Schroy 2011^22^ N=825 | Intention to Complete Screening Test^a^ DA+YDR: 4.4 (1.0) (n=280) DA: 4.3 (1.0) (n=269) Test Ordered by 12 months After Vsit DA+YDR: 73.6% DA: 80.7% DA+YDR vs DA: P = .048 | Test Ordered by 12 months Aafter Visit Control: 71.4%, P = .011 vs DA | Test Completed by 12 Months After Visit DA+YDR: 37.1% OR 1.03 (0.72, 1.48) vs control DA: 43.1% OR 1.30 (0.90, 1.87) vs control DA+YDR vs DA, P = .153 | Test Completed by 12 Months After Visit Control: 34.8%, P = .046 vs DA
Trevena, 2008^24^ | Intention to Screen Baseline 142/157 (90.4%) | Intention to Screen Baseline 139/157 (88.5%) | At One Month Completed FOBT 5.2% | At One Month Completed FOBT 6.6% P = .64
Trevena, 2008^24^ | Post-intervention 117/134 (87.3%) | Post-intervention 124/137 (90.5%), P = .40 | At One Month Completed FOBT 5.2% | At One Month Completed FOBT 6.6% P = .64

DA = decision aid; DA+YDR = decision aid plus “Your Disease Risk”; BE = barium enema; COL = colonoscopy; FOBT = fecal occult blood test; FS = flexible sigmoidoscopy; ns = not statistically significant;

a 5 point scale with 1 = not at all sure, 5 = completely sure

## PROSTATE CANCER

Table 11 Characteristics of Prostate Cancer Studies (k=18)

AUTHOR, YEAR (COUNTRY) | SCREENING OPTIONS | TARGET POPULATION | INTERVENTION (I) (n) COMPARATOR (C) (n) | SAMPLE CHARACTERISTICS | SETTING | LENGTH OF FOLLOW-UP % WITHDRAWALS | RISK OF BIAS
Davison, 1999^25^ (Canada) | Screening defined as both DRE & PSA | Male patients age 50-79 with a periodic health examination appointment with no prostate cancer diagnosis or evidence of mental confusion. | I: verbal & written information, including prostate cancer screening controversies, pros & cons, encouragement to discuss with MD (n=50) C: Attention control involving discussion about general issues (n=50) | Age(yrs): Mean 62.2 50 to 59: 21.5% 60 to 69: 17% 70 to 79: 12% | 1 family medicine clinic | Immediate Withdrawals: 0% | Sequence generation: Adequate Allocation concealment: Adequate Blinding: no Incomplete outcome data: unclear Selective outcome reporting: unclear Risk of Bias: Moderate
Evans, 2010^26^ (United Kingdom) | PSA | Men aged >50 | I1: Web-based DA, Prosdex (n=89) I2: paper version of Prosdex text (n=86) C1: Questionnaire control group (n=103) C2: no questionnaire control group (n=126) | Age 50-59 65% White 92.9% Black 0.4% Indian 0.4% Mixed Race 1.2% Other 1.1% Mean # previous PSAs 2.15 | 25 General practices from 9 Local Health Board areas in South Wales | Immediate, 6 months Loss to initial follow up: I1: 31% (40/129) I2: 32% (40/126) C1: 19% (24/127) Loss to 6 month follow up: I1: 46% (41/89) I2: 34% (29/86) C1: 33% (34/103) C2: 24% (32/132) | Sequence generation: Adequate Allocation concealment: Adequate Blinding: adequate Incomplete outcome data: Yes Selective outcome reporting: No Risk of Bias: Moderate
Frosch, 2003^27^ (United States) | PSA | Men aged >50 | I1: Web-based DA (N=114) I2: Video DA (N=112) | Age 62.1 White 91.1% African American 0.4% Hispanic 3.5% Asian 3.2% Other 0.4% Mean # previous PSAs 2.15 | 1 Preventive Medicine Clinic | Immediately post-visit Withdrawals: Video 5.7% Web: 17.5% | Sequence generation: Adequate – random number generator Allocation concealment: Adequate Blinding: no Incomplete outcome data: Yes – there was incomplete outcome data, handled by imputing the mean for some and pretest scores for others. This is a less rigorous approach than multiple imputation. Selective outcome reporting: Yes Risk of Bias: Moderate
Frosch, 2008^28^ (United States) | PSA | Male patients >50 | I1: Web-based Traditional Decision Aid (TDA) (n=155) I2: Web-based Chronic Disease Trajectory Model (DTM) (n=153) I3: combined TDA and DTM (n=152) C: links to public ACS and CDC prostate cancer screening websites (n=151) | Age 58.6 White 86% African American 2.8% Hispanic 5.2% Asian 3.9% Other 2.0 % Mean # previous PSAs 3.4 | 1 Preventive Medicine Clinic | Length of follow-up unclear (participants approached “after appointment completed” to assess outcomes) Withdrawals: TDA 23% DTM 25% TDA&DTM 22% Control 34% | Sequence generation: Computer algorithm used to randomize – Adequate Allocation concealment: Adequate Blinding: Unclear whether participants, providers, investigators, and/or outcome assessors were blinded. Incomplete outcome data: Yes – there was incomplete outcome data, handled by imputing the mean for some and pretest scores for others. This is a less rigorous approach than multiple imputation. Selective outcome reporting: Yes Risk of Bias: Moderate
Gattellari, 2003^29^ (Australia) | PSA | Male patients fluent in English, age 40-70 with no prostate cancer diagnosis | I: 32-page (3085 word) Evidence Based booklet distributed in clinic (n=126) C: 968 word pamphlet published by the Australian government (n=122) | Mean Age 54.0 Male 100% Previous PSA 36% | Practices of 13 General Practitioners in urban Sydney | Unclear Withdrawal I: 16% (n=106) C: 11% (n=108), NS | Sequence generation: Adequate (pre-randomized code). Allocation concealment: Adequate – pre-randomized assignment concealed from receptionists and General Practitioners by sealed envelope handed to patients. Blinding: Receptionists, general practitioners, and patients were blinded. It is not clear whether individuals conducting analysis were blinded. Incomplete outcome data: Yes –11-16% were not followed up, but no statistically differences across experimental groups on follow-up rates. Selective outcome reporting: unclear Risk of Bias: Moderate
Gattelari, 2005^30^ (Australia) | PSA | General Practitioners (GPs) who had ordered at least one PSA in past 12 months | I: Mailed information, telephone peer coaching, and education sessions (n=110 practices, 136 GPs) C: Mailed summary of PSA screening guidelines (n=110 practices, 141 GPs) | Age <35 3.3% 35-44: 22.7% 45-54: 40.8% 55-64: 19.8% 65+: 11.9% Missing: 1.4% Gender Male: 75.1% Female: 24.9% | Referral network of GPs in New South Wales Australia'S most populous state, recruited through large pathology service. 220 Clinics | Length of follow-up: 0-6-weeks (depending on outcome) Withdrawals: 1% | Sequence generation: Computer generated random number used to randomize – Adequate Allocation concealment: Adequate – GPs were randomized at the same time, Investigator responsible for randomization not involved in data collection. Blinding: Adequate Incomplete outcome data: Yes – there was incomplete outcome data, but no differences across experimental groups, and only 1% had no data, and outcome-specific missing rates unclear. Selective outcome reporting: unclear Risk of Bias: Moderate
Kripalani 2007^31^ (United States) | PSA, DRE | Men age 45-70; waiting for primary care appointment Excluded: history of prostate cancer, in police custody, not scheduled to see a primary care provider, ill, not fluent in English, corrected visual acuity worse than 20/60 | I1: High-detail patient educational pamphlet, PtEd, to promote shared decision making (n=86) I2: Low-detail “Talk to doctor” Cue handout (n=81) C: Traditional food pyramid (attention control) (n=83) | Age (yr): 56.5 Gender (Male %): 100 Race/Ethnicity (%): African American 90.4, white 8.0, other 1.6 Previous Screen (%): 68 Reading below 9^th^ grade level (%): 79 | One inner-city primary care clinic | Immediately post-visit 4% of patients could not be located for post-visit questions | Sequence generation: adequate Allocation concealment: adequate Blinding: health care providers and outcomes assessors were blinded Incomplete outcome data: no Selective outcome reporting: no Risk of Bias: Low
Krist, 2007^32^ (United States) | PSA | Men age 50 to 70 years; scheduled health maintenance examination Excluded: history of prostate cancer, no Internet access, planned to have blood work before visit, enrolled in another prostate cancer investigation, already enrolled in present study | I1: Web-based decision aid (n=226) I2: Paper version of decision aid (n=196) C: No pre-visit educational material (n=75) | Age (yr): 57 Gender (Male %): 100 Race/Ethnicity (%): white 91, African American 3 Previous Screen (%): 68 (PSA) | One large family practice center with a community-based family practice residency program | Immediately post-visit 87% of patients and 91% of physicians completed post-visit questionnaire | Sequence generation: adequate Allocation concealment: adequate Blinding: none Incomplete outcome data: 13% of patients did not complete post-visit questionnaire No Selective outcome reporting: No Risk of Bias: Moderate
Lepore, 2012^33^ (United States) | PSA | Men 45 to 70 years old, black African descent, accessible by telephone, have a primary care physician Excluded: prostate cancer test in past 12 months, history of prostate cancer | I: tailored telephone education about prostate cancer testing (n=244) C: telephone education about fruit and vegetable consumption (attention control) (n=246) All patients received an educational pamphlet | Age (yr): 55 Gender (Male %): 100 Race/Ethnicity (%): Caribbean 77 Previous Screen (%): 28 | Health insurance company of a healthcare workers' union | Interview 8 months after randomization Claims data collected for 2 years after enrollment 59/490 (12%) did not complete second survey; medical claims data available for all patients randomized | Sequence generation: adequate Allocation concealment: adequate Blinding: data collectors were blind to condition Incomplete outcome data: follow-up survey data missing for 12% Selective outcome reporting: No Risk of Bias: Moderate
Myers, 2011^34^ (United States ) Decision Counseling Trial (DCT) | PSA | Men 50 to 69 years old, no history of prostate cancer or benign prostatic hyperplasia, no PSA test in past 11 months | I: Structured decision counseling session (mean of 28 minutes) about prostate cancer screening plus generic note in medical chart to prompt physician to discuss prostate cancer (n=156) C: practice quality assessment survey (to match face time of intervention group) plus generic note in chart to prompt discussion of prostate cancer screening (n=157) All patients received a 12 page informational brochure on prostate cancer and screening | Age (yr): 56 Gender (Male %): 100 Race/Ethnicity (%): while 56, non-white 43 Previous Screen (%): NR | 2 primary care practice sites | Telephone survey about 7 days after office visit Medical records review about 120 days after visit Primary outcomes: data for 91% IDM outcome: data for 43% (required consent to audiotape) Screening outcome: data for 97% | Sequence generation: unclear Allocation concealment: unclear Blinding: NR Incomplete outcome data: 9% missing data for primary outcome (reasons not reported) Selective outcome reporting: No Risk of Bias: Moderate
Partin, 2004^35^ Partin 2006^36^ (United States) | PSA | Male veterans, age 50 and older, no prostate cancer, scheduled for general internal medicine appointment | I1: pamphlet (developed for study) (n=384) I2: video (23 min; developed by FIMDM) (n=384) C: usual care (n=384) | Age (yr): 68 Gender (Male %): 100 Race/Ethnicity (%): non-Caucasian 5 Previous Screen (%): 70 | General internal medicine clinics at 4 VA facilities | Telephone survey 1 week after visit Medical record review at 2 weeks and 1 year 42/1152 (4%) found to be ineligible; 893/1110 (80%) completed follow-up survey | Sequence generation: adequate Allocation concealment: unclear Blinding: providers and outcomes assessors were blinded Incomplete outcome data: outcome data for 76% of patients randomized; explained Selective outcome reporting: No Risk of Bias: Moderate
Schapira, 2000^37^ (United States) | PSA DRE | Men aged 50 to 80 years; outpatient encounter at VA Medical Center Excluded: history of prostate or other cancer, previous prostate ultrasound study or biopsy, cystoscopy, prior prostate surgery, active genitourinary symptoms, cognitive impairment, expected life expectancy <2 years, employee of the VA Medical Center | I: Pamphlet – decision aid with information about screening and treatment (plus educational information included in comparator pamphlet) (8 pages) (n=122) C: Pamphlet – basic prostate cancer information (no information on risks and benefits of screening) (5 pages) (n=135) | Age (yr): 70 Gender (Male %): 100 Race/Ethnicity (%): white 92, black 3 Previous Screen (%): NR | VA Medical Center outpatient clinic | Post-intervention Follow-up visit 2 weeks after initial study visit | Sequence generation: Unclear Allocation concealment: Unclear Blinding: Unclear Incomplete outcome data: No Selective outcome reporting: Not all items from belief assessment were reported Risk of Bias: Moderate
Sheridan, 2012^38^ (United States) (NOTE: study was originally designed as 2 studies – 1) intervention vs attention control [highway safety video] and 2) intervention plus additional information on 2 other men'S health screening services vs attention control [highway safety video]; results were combined) | PSA | Men who were age-eligible for prostate cancer screening (40-80 years old, no prior history of prostate cancer, seen in the practice for at least 1 year, physician agreed to participate in study Excluded: acute medical visit, evidence of serious medical illness | I: Video, coaching session, brochure (n=60) C: educational video on highway safety (n=70) | Age (yr): 58 Gender (Male %): 100 Race/Ethnicity (%): white 64, African American 18 Previous Screen (%): 52 (44 intervention, 59 control) | 4 Internal medicine practices (1 academic, 1 community in 2 cities) | Follow-up questionnaires; a. post-intervention; b. post-appointment (same day); Review of medical records approximately 9 months after visit to determine whether screening was done Withdrawals: 2/130 (1.5%) from intervention group | Sequence generation: Adequate Allocation concealment: Unclear Blinding: physicians were unaware of patient group assignment Incomplete outcome data: Yes – no data from 2 patients Selective outcome reporting: No Risk of Bias: Moderate
Taylor, 2013^39^ (United States) | PSA, DRE | Men age 45-70, English speaking, ability to provide informed consent, independent living, appointment in next 24 months Excluded: history of prostate cancer | I1: Web DA (n=625) I2: Print DA (n=628) C: UC (n=626) | Age (yr): 56.9 Gender (Male %): 100 Race/Ethnicity (%): white 56.2, African American 39.9, other 3.9 Previous Screen (%): 86.3 | 3 health systems in 1 city | Follow up at 1 month and 13 months Retention rate 1 month 89%, 13 months 84% | Sequence generation: Adequate Allocation concealment: Unclear Blinding: yes Incomplete outcome data: Yes – Retention rate 1 month 89%, 13 months 84% Selective outcome reporting: No Risk of Bias: Low
Volk, 1999^40^ Volk, 2003^41^ (1 year follow-up) (United States) | PSA | Men 45-70 years old, no history of prostate cancer | I: Educational video (from Foundation for Informed Medical Decision Making, Inc.) and accompanying brochure (n=80) C: No intervention before visit; brochure sent after 2 week follow-up assessment (n=80) | Age (yr): 59 Gender (Male %): 100 Race/Ethnicity (%): white 61, African American 19, Mexican American 16 other 4 Previous Screen (%): 41 | Family medicine clinic | Videotape evaluated after viewing 2 week follow-up assessment (Volk 1999) 1 year follow-up[ assessment (Volk 2003) Withdrawals at 2 weeks: 2/160 (1.3%) from intervention group Withdrawals at 1 year (total): 23/160 (14%) | Sequence generation: Adequate Allocation concealment: Adequate Blinding: Physicians were unaware of patient assignment; interviewers and patients were not blinded Incomplete outcome data: Yes – no data from 2 intervention group patients (1 died, 1 unavailable) Selective outcome reporting: No Risk of Bias: Moderate
Volk, 2008^42^ (United States) | PSA | Men 50 to 70 years old if not African American (40 to 70 if African American), visit to clinic for non-acute care, no history of prostate cancer | I: Interactive multimedia decision aid (n=224; 76 at low literacy site, 148 at high literacy site) C: Audiobooklet without interactivity and entertainment factors (n=226; 73 at low literacy site, 153 at high literacy site) | Patients completing 2 week follow-up n=89 at low literacy site Age (yr): 56 Gender (Male %): 100 Race/Ethnicity (%):African American 73, , Hispanic 9, white 18 Previous Screen (%): 37 n=263 at high literacy site Age (yr): 57 Gender (Male %): 100 Race/Ethnicity (%):African American 17 , Hispanic 8, white 65 Previous Screen (%): 75% | General medicine clinic at publicly funded hospital (low health literacy site) and university-affiliated family medicine clinic (high health literacy site) | Post-intervention and 2 weeks Withdrawals: 13/450 (2.9%) at post-intervention follow-up 85/437 (19%) at 2 week follow-up 98/450 (21.8%) total (including 16% from high literacy site and 40% from low literacy site) | Sequence generation: Unclear Allocation concealment: Unclear Blinding: Unclear Incomplete outcome data: Total of 21.8% lost at 2 week follow-up Selective outcome reporting: No Risk of Bias: Moderate
Watson, 2006^43^ (United Kingdom) | PSA | Men age 40 to 75 years, no history of prostate cancer | I: Copy of brief patient decision aid and questionnaire (n=980 randomized; 468 analyzed) C: Questionnaire only (n=980 randomized, 522 analyzed) | Age (yr): sample was stratified by age group (40-49, 50-59, 60-69, 70-75) Gender (Male %): 100 Race/Ethnicity (%): white 97%, black 1%, Asian 1% Previous Screen (%): 16 | 11 general practices in England and Wales | Intervention and control components were sent to patients followed by a single reminder 5.6% did not receive intervention 54% of delivered questionnaires were returned and eligible 7 questionnaires (of 475 returned by intervention group) were excluded; no exclusions in control group | Sequence generation: Adequate Allocation concealment: Adequate (mailed intervention) Blinding: N/A – self-administered questionnaire Incomplete outcome data: Yes Selective outcome reporting: No Risk of Bias: Moderate
Wilkes, 2013^44^ (United States) | PSA | Men age 55 to 65 years, no serious comorbidity, English speaking | I1: Interactive Web-based educational program (MD-Ed); 30 min (19 waiting areas; 41 physicians with 246 patients) 12: MD-Ed plus Web-based patient activation (30 min) (MD-Ed+A) (19 waiting areas; 36 physicians with 113 patients) C. usual practice (17 waiting areas; 43 physicians with 353 patients) All patients had access to CDC brochure in waiting area | Patients (n=581 analyzed) Age (yr): 63 Gender (Male %): 100 Race/Ethnicity (%): 82% white, 8% Hispanic, 8% African American, 5% Asian Previous Screen (%): 83% | 2 large primary care networks associated with academic medical center, 2 staff model HMOs; 1 medical group practice network (all in California) | Length of follow-up: Varied (study complete after standardized patient visit) Withdrawals: No physicians withdrew, 15 (12.5%) did not start intervention and were analyzed with usual practice group 14% of patients did not return questionnaire or had incomplete data; additional 5% were found to have prior prostate cancer; 33 patients of physicians who did not start intervention were analyzed with usual practice group | Sequence generation: Adequate Allocation concealment: Adequate Blinding: patients were not aware of physician assignment (cluster randomized trial with waiting areas randomized); physicians were not aware of which patients were involved in the study or who completed the educational program Incomplete outcome data: Yes; 14% of patients did not return questionnaire and 5% who returned questionnaire had prior prostate cancer Selective outcome reporting: No Risk of Bias: Moderate

k = number of studies; DA=Decision Aid; DRE = digital rectal examination; FIMDM = Foundation for Informed Medical Decision Making, Inc.; HMO = health maintenance organization; PSA = prostate-specific antigen

Table 12 Characteristics of Interventions from Prostate Cancer Studies

AUTHOR, YEAR | DELIVERY MODE | DELIVERY TIMING and LOCATION | VALUES CLARIFICATION EXERCISE | RISK COMM. METHOD | CONSIDERED HEALTH LITERACY or NUMERACY | RESOURCES (COST, STAFF, PHYSICAL)
Davison, 1999^25^ | Verbal & written | Before a periodic health examination (PHE) in clinic | None | Not clear | Not clear | Not clear
Evans, 2010^26^ | Web / text of web | Identified from patient registry but not tied to appointment At home | Decision stacker (web) | Not clear | Not clear | Not clear
Frosch, 2003^27^ | Web version of video DA | Before health appraisal appointment Anywhere (web) in clinic (video) | None | Not clear | Not clear | Not clear
Frosch, 2008^28^ | Internet (4 conditions) | 2-3 weeks before Health Appraisal appointment Anywhere | DTM: Time trade off exercise and visual analog ratings | Not clear | Not clear | Not clear
Gattellari, 2003^29^ | Print – distributed in clinic | Prior to appointment in general practice clinic | Social matching - Series of statements consistent with PSA- - determine which statements “sound like them” | Pictograms and flow diagrams | Flesch-Kinkaid grade level for intervention booklet =7.3 Flesch-Kinkaid level for comparison booklet 11.2 | Not clear
Gattelari, 2005^30^ | Audio, video information packages; Booklets and peer coaching | Not tied to a specific appointment Unclear | None | Not clear | Not clear | Medical peer educators to deliver peer coaching sessions
Kripalani, 2007^31^ | Pamphlets (High-detail, low-detail) | In waiting room before appointment | No | Pictograph | Written at 6^th^ grade level, designed for low-literacy patients; assessed subject literacy | Trained interviewers
Krist, 2007^32^ | Internet or paper version | Within 2 weeks of visit Home | None | Not clear | Not clear | Not clear
Lepore, 2012^33^ | Telephone (Initial 20 min call, brief follow-up call approx. 1 week later) | Health insurance o appointment Home | Interventionists described 5 potential risks and 5 potential benefits of testing and asked participant after each one whether the information influenced interest in getting tested | Not clear | Pamphlet was designed for men with low literacy Knowledge test items were piloted to ensure comprehension | Telephone interventionists (graduate level health-educators)
Myers, 2011^34^ | Face-to-face counseling session | Scheduled visit for non-acute care Clinic | Counseling session included discussion of factors influencing screening decision and relative influence and strength | Not clear | Not clear | Study nurse educator (training sessions and patient sessions)
Partin, 2004^35^ Partin, 2006^36^ | Video or pamphlet | Mailed 2 weeks before appointment Home | None | Not clear | Pamphlet written at 6^th^ grade level Video designed for 100% comprehension at 10^th^ grade level | Not clear
Schapira, 2000^37^ | Pamphlet | 2 weeks before appointment with physician or research physicians Clinic | None | Pictograph to show frequencies of outcomes per 100 men | Research assistant present and available to answer questions when patients read pamphlets Assessment tools were pilot-tested | Research assistant present
Sheridan, 2012^38^ | 1. Video (12 minutes); 2. Coaching session (8 minutes) led by trained health counselor; 3. Supplemental brochure | 1 hour prior to appointment Private room at the clinic | a. In video: social matching with 2 men making opposite decisions using the same facts; b. In coaching session: men to read series of 2 opposing statements and chose which best represented their thinking | Not clear | Not clear | 1 hour educational session for physicians 8 min coaching time
Taylor, 2013^39^ | Web-based or Print DA | Reviewed at home | Yes | Pictographs | DAs have 8^th^ grade reading level; assessed health-related numeracy | Not clear
Volk, 1999^40^ Volk, 2003^41^ (1 year follow-up) | Video (20 min) Or brochure on risks & benefits | Before scheduled office visit In clinic | None | Not clear | Knowledge assessment tool written at 5^th^ grade reading level; Spanish version available if patient requested | Office visit for video
Volk, 2008^42^ | “Edutainment” decision aid combining storyline with factual medical information | Before scheduled office visit In clinic | Social-matching – patient asked to pick character who most resembles how they feel | Not clear | Had low health literacy and high health literacy sites | Not clear
Watson, 2006^43^ | Printed material | Not associated with a visit Reviewed at home | None | Not clear | “conformed to accepted standards for the provision of patient information;” decision aid was field-tested with the target population | Not clear
Wilkes, 2013^44^ | Interactive Web-based education program | Physician education prior to all patient visits (location not specified) Patient education 60 min prior to visit (in clinic) | Educational programs included questions about individual'S values and preferences | Visual risk comparison diagrams (MD and patient programs) Vignettes for potential harms (patient program) | Not specified | Research associate to assist patients in completing Web-based program Standardized patients (8 actors, 20 hours of training each, 120 physician visits)

Table 13 Decision Quality Outcomes Assessed in Prostate Cancer Studies

AUTHOR, YEAR | KNOWLEDGE | | PATIENT ROLE IN DECISION | | VALUES CLARITY
AUTHOR, YEAR
AUTHOR, YEAR | Intervention | Control | Intervention | Control | Intervention | Control
Davison, 1999^25^ | - | - | Active 31/50 (62%) Passive 9/50 (18%) Collaborative 10/50 (20%) Z=-4.07, P < .001 | Active 11/50 (22%) Passive 19/50 (38%) Collaborative 20/50 (40%) | - | -
Evans, 2010^26^ | Mean (Range -12 to +12) Prosdex 4.90 Paper 5.40 Prosdex vs paper U/mn=0.47 (95%CI 0.39, 0.55), P = .48 | Questionnaire control group (QCG) 2.17 Prosdex vs QCG U/mn=0.70 (95%CI=0.62, 0.76), P < .001 | - | - | - | -
Frosch, 2003^27^ | Knowledge about prostate cancer screening and testing (0-5 scale): Pretest 1.84 (0.10) Posttest 1.92 (0.90) | Pretest 2.90 (0.12) Posttest 3.47 (0.12) P < .001 | - | - | - | -
Frosch, 2008^28^ | Mean (SD) – imputed TDA 8.14 (0.15) DTM 7.69 (0.15) Combined 7.71 (0.15) | Mean (SD) – imputed 7.24 (0.16) | - | - | DCS Values clarity subscale TDA 32.25 DTM 36.62 Combined 38.24 TDA vs other groups, P < .05 | DCS Values clarity subscale 37.93
Frosch, 2008^28^ | Mean (SD) – complete data TDA 8.65 (0.18) DTM 8.03 (0.18) Combined 8.03 (0.18) | Mean (SD) – complete data 7.49 (0.19) | - | - | DCS Values clarity subscale TDA 32.25 DTM 36.62 Combined 38.24 TDA vs other groups, P < .05 | DCS Values clarity subscale 37.93
Gattellari, 2005^29^ | Mean 6.1 | 4.8 P ≤ .001 | Decisional Control-Patient passive 5/135 (3.7) | Decisional Control-Patient passive 35/139 (25.2) OR=0.11 (0.04-0.31), P < .001 | - | -
Gattellari, 2003^30^ | Mean % correct = 50% (no SD provided) P = .049 | Mean % correct = 45% | - | - | Mean (SD) Pretest 2.2 (1.31) Posttest 1.7 (1.4-2.0) | Mean (SD) Pretest 2.4 (1.33) Posttest 1.4 (1.0-1.6)
Kripalani, 2007^31^ | - | - | Frequency of prostate cancer discussion with health care provider PtEd: 50.0%, aOR=1.92 (95%CI 1.01, 3.65), P < .05 Cue: 58.0%, aOR=2.39 (95%CI=1.26, 4.52), P = .008 | Frequency of prostate cancer discussion with health care provider Control: 37.3, P = .03 | -
Kripalani, 2007^31^ | - | - | Proportion of patients who initiated the discussion: PtEd: 47.6%, P < .01 Cue: 40.0%, P < .01 | Proportion of patients who initiated the discussion: Control: 9.7% | -
Krist, 2007^32^ | % of knowledge questions answered correctly: Web-based: 69% Brochure: 69% | % of knowledge questions answered correctly: Control: 54% P < .001 vs either Web-based or brochure interventions | CPS (n=431) Web-based: increased involvement in relative to control (P = .03) A (Complete patient control) = 17% B = 39% C (Collaborative) = 36% D = 3% E (Complete physician control) = 5% Brochure: increased involvement relative to control (P = .03) A = 23% B = 31% C = 36% D = 4% E = 6% | CPS Control: A (Complete patient control) = 11% B = 34% C(Collaborative) = 36% D = 10% E (Complete physician control) = 9% | -
Lepore, 2012^33^ | % Correct Pretest 51.7% (SE 0.012) Posttest 61.6% (SE 0.009) | % Correct Pretest 49.6% (SE 0.012) Posttest 54.7% (SE 0.009) Condition by time interaction; P < .001 | Talked to MD about PC screening [underlined: Intervention:] 34/215 (15.8%) Exp(B) 2.127, P < .001 | Talked to MD about PC screening [underlined: Control:] 18/216 (8.3%) | - | -
Myers, 2011^34^ | 10 items, range 1 to 10 Baseline: 3.8 (1.9) Endpoint : 5.3 (2.0) | Baseline: 3.6 (2.1) Endpoint: 4.4 (2.1); P = .001 | - | - | - | -
Partin, 2004^35^ Partin, 2006^36^ | 10 items, range 1 to 10 Pamphlet: 7.3 [7.0, 7.5]; P = .001 vs control Video: 7.4 [7.2, 7.7]; P = .03 vs control | Usual care: 6.9 [6.7, 7.1] | Discussed PSA Video: 35% P = .33 vs control Pamphlet: 41% P = .03 vs control | Discussed PSA Control: 32% | - | -
Schapira, 2000^37^ | 18 items Baseline: 11.7 (2.4) Post-intervention: 15 (2.3) | 18 items Baseline: 11.4 (2.4); P = .32 Post-intervention: 14.1 (2.7); P < .01 | - | - | - | -
Sheridan, 2012^38^ | % men have “key knowledge” (correct responses to 4 key questions) 47% (27/58) | % men have “key knowledge” (correct responses to 4 key questions) 13% (9/70) Absolute difference 34% [95%CI 19, 50] aRR 4.28 [95% CI 2.30, 6.45] | % men reporting shared decisions, post-visit 74% (28/38) | % men reporting shared decisions, post-visit 76% (39/51) Absolute difference -3% [95% CI -21, +15%] aRR 0.96 [95%CI 0.67, 1.15] | ‘PSA is a Decision’ score 64% (37/58) | ‘PSA is a Decision’ score 23% (16/70) Absolute difference 41% [95% CI 25, 57%] aRR 2.79 [95%CI 1.96, 3.47]
Taylor, 2013^39^ | PCa screening knowledge, mean (SD) 1 mo Web DA: 13.5 (3.4) Print DA: 13.5 (3.5) Print vs web P = .90 13 mo Web DA: 12.6 (3.4) Print DA: 12.7 (3.3) Print vs web P = .65 | PCa screening knowledge, mean (SD) 1 mo 11.1 (3.1) UC vs web P = .001 UC vs print P = .001 13 mo 11.0 (3.0) UC vs web P = .001 UC vs print P = .001 | - | - | - | -
Volk, 1999^40^ Volk, 2003^41^ (1 year follow-up) | Baseline: 2.7 (of 10 questions) correct 2 weeks: 4.8 Change: +2.1, P = .001 1 year follow-up: 3.8 (of 10 questions) correct | Baseline: 2.8 (of 10 questions) correct 2 weeks: 3.1 Change: +0.3, P = .19 1 year follow-up: reported unchanged Across data collection periods: P < .001 for group differences | - | - | - | -
Volk, 2008^42^ | Both low- and high-literacy site patients had significant improvements in knowledge regardless of decision aid received; no significant differences between the decision aids in subject'S knowledge gains | | PSAS-Low Literacy Site^a^ Total: 1.66 [1.56, 1.76] PSAS-High Literacy Site^a^ Total: 2.41 [2.34, 2.47] | PSAS-Low Literacy Site Total: 1.75 [1.67,1.84]; P=0.15 PSAS-High Literacy Site Total: 2.45 [2.39, 2.47]; P = .38 | - | -
Watson, 2006^43^ | U.K. specific measure developed for the study (12 items) Median 9.0 (range 0-12) | U.K. specific measure developed for the study (12 items) Median 3.0 (range 0-12); P < .0001) | Patient makes decision: 106/985 (11%) Patient makes decision after considering doctor'S opinion: 421/985 (43%) Shared decision: 324/985 (33%) Doctor makes final decision after considering patient'S opinion: 64/985 (6%) Doctor makes decision: 70/985 (7%) | | Decisional balance score (mean) -3.5 (SE 0.9) | +3.3 (SE 0.8); P < .0001 indicating less favorable assessment of the “pros” of screening vs the “cons” in the intervention group
Wilkes, 2013^44^ | - | - | Physician report: Change in Shared Decision Making (Kaplan Scale), sum mean score (SD) MD-Ed: 0.2 (1.5) (AMD -0.05 [-0.72, 0.61] vs control) MD-Ed+A: 0.1 (1.5) (AMD -0.10 [-0.77, 0.56] vs control) | Physician report: Change in Shared Decision Making (Kaplan Scale), sum mean score (SD) Control: 0.2 (1.5) | - | -
Wilkes, 2013^44^ | - | - | Patient report: Perception of shared decision making post-visit^b^ MD-Ed: 11.4 (3.0) (AMD -0.29 [-1.30, 0.71] vs control) MD-Ed+A: 12.3 (3.0) (AMD 0.87 [-0.17, 1.90] vs control) | Patient report: Perception of shared decision making post-visit Control: 11.8 (3.0) | - | -

aOR = adjusted odds ratio; aRR = adjusted risk ratio; AMD = adjusted mean difference; NR = not reported; MD-Ed = physician education; MD-Ed+A = physician education with patient activation

a Low literacy version of Patient Self-Advocacy Scale (PSAS) used at low literacy site; standard 12-item version used at high literacy site; lower scores indicate greater self-advocacy but scores across sites should not be compared

b Kaplan shared decision making instrument (modified to be specific for prostate cancer screening); sum of 4 elements; 4=strongly disagree, 16=strongly agree

Table 14 Decision Impact Outcomes Assessed in Prostate Cancer Studies

AUTHOR, YEAR) | DECISIONAL CONFLICT^a^ | | USE OF HEALTH SERVICES | | DECISION SATISFACTION
AUTHOR, YEAR) | Intervention | Control | Intervention | Control | Intervention | Control
Davison, 1999^25^ | 28.52 Effect size: Z= -3.602, P < .00001 | 35.20 | - | - | - | -
Evans, 2010^26^ | Prosdex 40.37 Paper 38.49 Prosdex vs paper U/mn=0.56 (95%CI=0.47-0.64), P = .18 | QCG 47.73 Prosdex vs control U/mn=0.32 (95%CI=0.25-0.40), P < .001 | - | - | - | -
Frosch, 2003^27^ | - | - | - | - | - | -
Frosch, 2008^28^ | DCS subscale scores Feel informed TDA 23.4 DTM 27.23 Combined 27.3 Value clarity TDA 32.3 DTM 36.6 Combined 38.2 Feel supported TDA 30.5 DTM 33.8 Combined 35.4 | DCS subscale scores Feel informed 29.7 Value clarity 37.9 Feel supported 35.2 P < .05 TDA vs other groups for 3 subscales | - | - | - | -
Gattellari, 2003^29^ | DCS Uncertainty subscale mean 8.1 (no sd) p=.93 Factors contributing to uncertainty subscale mean 21.6 (no SD) P ≤ .001 | DCS Uncertainty subscale mean 8.1 Factors contributing to uncertainty mean 24.3 | - | - | - | -
Gattellari, 2005^30^ | Mean score (range 9-45) No SD provided 25.4 (95%CI 24.5-26.3) | Mean score (range 9-45) No SD provided 27.8 (95%CI 26.6-29.0), P = .0002 | - | - | - | -
Kripalani, 2007^31^ | - | - | - | - | - | -
Krist, 2007^32^ | Web-based: 1.55 (range 1, 2.7) Brochure: 1.54 (range 1, 2.8) | Control: 1.58 (range 1, 3.2) p=NS vs intervention groups | Patient report of minutes discussing PCa, mean Internet: 5.1 (range 0, 15) Brochure[underlined: :] 5.3 (range 0, 25) | Patient report of minutes discussing PCa, mean UC: 5.2 (range 0, 20) NS | - | -
Lepore, 2012^33^ | 34.15 (SE 1.64) | 39.85 (SE 1.64) F(1,427)=6.05, P < .05 | | | - | -
Myers, 2011^34^ | 0-4 (higher scores indicated higher decisional conflict) 0.29 (0.34) | 0.32 (0.49) P = .62 | - | - | - | -
Partin, 2004^35^ Partin, 2006^36^ | - | - | - | - | - | -
Schapira, 2000^37^ | - | - | - | - | - | -
Sheridan, 2012^38^ | - | - | - | - | - | -
Taylor, 2013^39^ | 1 mo Web DA: 12.7 (21.0) Print DA: 12.2 (19.3) Print vs web P = .70 13 mo Web DA: 11.4 (19.5) Print DA: 10.7 (16.9) Print vs web P = .61 | 1mo 20.0 (23.7) UC vs web P = .001 UC vs print P = .001 13 mo 15.0 (21.2) UC vs web P = .001 UC vs print P = .001 | - | - | Satisfaction with Decision Scale^b^; % high satisfaction: 1 mo Web DA: 52.2 Print DA: 60.4 Print vs web P = .01 13 mo Web DA: 50.4 Print DA: 55.7 Print vs web P = .10 | Satisfaction with Decision Scale; % high satisfaction: 1 mo 45.5 UC vs web P = .001 UC vs print P = .03 13 mo 49.8 UC vs web P = .85 UC vs print P = .06
Volk, 1999^40^ Volk, 2003^41^ (1 year follow-up) | - | - | - | - | SWD^b^ Mean = 24.3 [23.7, 25.0] | SWD Mean = 23.8 [22.9, 24.7] NS
Volk, 2008^42^ | Low Literacy Site DCS^c^ Total: 12 [5, 19] High Literacy Site DCS^c^ Total: 13 [10, 15] | Low Literacy Site DCS Total: 22 [15, 28]; P = .04 High Literacy Site DCS Total: 15 [13, 17]; P = .15 | - | - | - | -
Watson, 2006^43^ | - | - | - | - | - | -
Wilkes, 2013^44^ | - | - | - | - | - | -

DA = decision aid; NA = not applicable; SA = strongly agree; SD = strongly disagree

a Scores are mean of Decisional Conflict Scale (DCS) unless otherwise noted; higher scores indicate greater decisional conflict

b Satisfaction with Decision Scale (SWD): 6 items, 5 point scale

c Low literacy version (10 item) of DCS used at low literacy site; standard 16-item version used at high literacy site; scores across sites should not be compared

Table 15 Decision Action Outcomes Assessed in Prostate Cancer Studies

AUTHOR, YEAR | SCREENING INTENTION | | SCREENING BEHAVIOR
AUTHOR, YEAR
AUTHOR, YEAR | Intervention | Control | Intervention | Control
Davison, 1999^25^ | - | - | DRE and PSA: 28% | DRE and PSA: 21% “no significant differences”
Evans, 2010^26^ | % men who were very likely to or definitely would get PSA Prosdex: 40 (n=89) Paper: 53 (n=86) Prosdex vs paper: U/mn=0.43 (95%CI 0.35, 0.51), P = .10 | % men who were very likely to or definitely would get PSA QCG: 58 (n=103) Prosdex vs QCG: U/mn=0.40 (95%CI 0.32, 0.48), P = .02 | 6 month PSA uptake - % (n) Prosdex: 3.1 (4/127) Paper: 9.1 | 6 month PSA uptake - % (n) QCG: 8.9 (11/123) Prosdex vs QCG: Pearson chi-square P = .014 No QCG: 1.6 (2/126)
Frosch, 2003^27^ | | | 91.9% PSA request | 81.5% PSA request P < .05
Frosch, 2008^28^ | - | - | Reduction in PSA sx pre-post (%) TDA 9.1 DTM 8.7 Combined 5.3 | Reduction in PSA sx pre-post (%) 3.3 Single intervention vs combined or control group (OR=3.31, 95% CI 1.01, 10.74, P = .047)
Gattellari, 2005^29^ | Would not opportunistically discuss PSA 112/135 (83) Would not opportunistically sx 102/135 (75.6) Would not order PSA for men with LUTS 90/135 (66.7) | Would not opportunistically discuss PSA 93/140 (66.4) Would not opportunistically sx 41/140 (29.3) Would not order PSA for men with LUTS 4/140 (2.9) | Median # tests ordered per provider (IQR) 1 (0-2) | Median # tests ordered per provider (IQR) 2 (0-5) RR 0.52 (95% CI 0.38, 0.75), P = .0004
Gattellari, 2003^30^ | Definitely interested in PSA in next 12 months 27/106 (26%) Quite a lot 11/106 (11%) Somewhat 19/106 (18%) Definitely not interested in PSA in next 12 months 23/106 (22%) | Definitely interested in PSA in next 12 months 25/108 (23%) Quite a lot 14/108 (13%) Somewhat 21/108 (20%) Definitely not interested in PSA in next 12 months 25/108 (23%) | - | -
Kripalani, 2007^31^ | - | - | PSA test ordered, % (N) PtEd 14.1% (12) vs control: aOR=7.62, 95%CI 1.62, 35.83, P = .01 Cue 12.3% (10) vs control: aOR=5.86, 95%CI 1.24, 27.81, P = .03 | PSA test ordered, % (N) 2.4% (2)
Kripalani, 2007^31^ | - | - | DRE documented, % (N) PtEd 4.7% (4) vs control: aOR=0.85, 95%CI 0.21, 3.37, P = .81 Cue 6.2% (5) vs control: aOR=1.04, 95%CI 0.29, 3.76, P = .95 | DRE documented, % (N) 6.0 (5)
Krist, 2007^32^ | - | - | PSA test ordered Web-based Patient report: 86% Physician report: 86% (P = .06 vs control) Brochure Patient report: 83% Physician report: 85% (P = .04 vs control) | Control Patient report: 85% Physician report: 94% (P = .06 for patient vs physician)
Lepore, 2012^33^ | Plan to test for prostate cancer Pretest: 61% Posttest: 81% | Plan to test for prostate cancer Pretest: 59% Posttest: 81% P = ns | Verified PSA 1 year: 45% 2 year: 63% | Verified PSA 1 year: 46% 2 year: 67% P = ns
Myers, 2011^34^ | - | - | Within 120 days of visit 63% (n=152) Visit with physician aware of screening controversy: 64% Visit with physician unaware of screening controversy: 60% | Within 120 days of visit 71% (n=153) OR 0.67 [0.41, 1.08]; P = .102 Physician aware of controversy: 81% (P = .004) Physician unaware of controversy: 50% (P = .37)
Partin, 2004^35^ Partin, 2006^36^ | Intend to have PSA in next year Video: 63%; P < .05 vs control Pamphlet: 65%; P < .05 vs control | Control: 74% | PSA within 2 weeks Video: 29% Pamphlet: 28% PSA within 1 year Video: 70% Pamphlet: 67% | PSA within 2 weeks Control: 29% PSA within 1 year Control: 69% All P = ns
Schapira, 2000^37^ | - | | Prostate cancer screening completed 82% | 84% (P = .60)
Sheridan, 2012^38^ | 26/58 (45%) | 55/70 (79%) Absolute difference -34% [-50, -18] aRR 0.18 [0.06, 0.48] | After visit 4/58 (11%) | After visit 16/70 (31%) Absolute difference -21% [-38, -4] aRR 0.42 [0-.14, 1.24]
Sheridan, 2012^38^ | 26/58 (45%) | 55/70 (79%) Absolute difference -34% [-50, -18] aRR 0.18 [0.06, 0.48] | At 9 month review 11/58 (19%) | At 9 month review 29/70 (41%) Absolute difference -22% [-38, -7] aRR 0.76 [0.50, 0.97]
Taylor, 2013^39^ | - | - | Self-reported screening (PSA or DRE), % (n) Web DA: 59.3 (258) Print DA: 59.5 (282) Web vs Print P = .95 | Self-reported screening (PSA or DRE), % (n) 56.3 (281) Wed vs UC P = .35 Print vs UC P = .25
Volk, 1999^40^ Volk, 2003^41^ (1 year follow-up) | Preferring to have PSA test Baseline: 62/78 (79%) 2 weeks: 48/78 (62%) P = .01 | Preferring to have PSA test Baseline: 62/80 (78%) 2 weeks: 64/80 (80%) P = .82 Absolute difference 18.5% [4.6, 32.4]; P = .009 | During 1 year follow-up DRE: 26/70 (37%) PSA: 24/70 (34%) | During 1 year follow-up DRE: 26/67 (39%); P = .84 PSA: 37/67 (55%); P = .01
Volk, 2008^42^ | - | - | - | -
Watson, 2006^43^ | 119/465 (25.6%) reported positive testing intentions | 149/512 (29.1%) reported positive testing intentions OR 0.82 [0.61, 1.09]; P = .17 | - | -
Wilkes, 2013^44^ | - | - | Reported that PSA tests were ordered for 32% of patients overall with similar frequency among groups

k = number of studies; DRE = digital rectal examination; FOBT = fecal occult blood test; W&S = wait and see; BE = barium enema; COL = colonoscopy; PSA = prostate specific antigen; ns = not statistically significant; OR = odds ratio; aOR = adjusted odds ratio; aRR = adjusted risk ratio; sx = screen