# PEER REVIEW COMMENTS/AUTHOR RESPONSES

REVIEWER COMMENT | RESPONSE
1. Are the objectives, scope, and methods for this review clearly described?
No. Objectives and scope are clearly described. I would like to see more details in the methods section about:; 1. USE OF HEALTH SERVICES. This is eventually defined on P 38, but a more detailed explanation should appear earlier. My first thought was that it was measuring utilization related to undergoing testing.; 2. COMPARATORS: Clarify earlier in the methods section that “usual care” comparators = effectiveness studies, “alternative SDM” = comparative effectiveness studies.; 3. VALUE-CONCORDANCE: Clarify the meaning of the concepts of values clarity and value concordance and explain how these concepts are being measured with the various instruments. Would also suggest explaining a “values clarification exercise.” I found the values concepts to be incompletely described and/or used interchangeably, making it difficult to interpret the findings (“clearer values, higher values clarity, “decreased value assessments,” “clear values that matched the intention,” etc.); I would suggest explicitly explaining the reason for excluding studies that measured only Decision Action—presumably your reliance on the OSDF framework. I would also have liked to seen the reference list for the studies excluded for this criterion. From reading meta-analyses of cancer screening trials, I know that many RCT of decision aids have been excluded—and I suspect that it was for their limited outcome focus. | Thank you. We included more details and definitions throughout the report, including :; 1. Use of health services: We included a definition in both the executive summary (pg 1, paragraph 2) and the main report (pg 12, paragraph 1).; 2. Comparators: We made our language consistent and used effectiveness studies, comparative effectiveness studies, and attention control studies throughout, and included definitions (pg 21 paragraph 1).; 3. Value-concordance: We made our language consistent, using values clarity and defining the construct (pg 1 paragraph 2) and describing it with the authors' measurement in a new table with information about measures (Appendix E). We also included a definition of a values clarification exercise (pg 7, paragraph 1).; We added information on the Ottawa Decision Support Framework and how it guided our review (pg 13 paragraph 3; pg 14 paragraph 1), and why some key decision aid studies were excluded (pg 14 paragraph 1; pg 16 paragraph 5). Additionally, we prepared a table of excluded studies (Appendix B).
Yes. In general, the objectives, scope, and methods for this review are clear. However, in the summary, I would add to KQ1 “for cancer screening” after SDM interventions (line 25 p. 1). I would also consistently say “SDM interventions” and not just interventions (line 29 p. 1, line 12, p. 2, line 28 p. 11, and others throughout). Also, my biggest concern is that the authors should clarify what they mean by SDM and whether they mean any form of SDM or specifically patient decision aids? It seems they mean any form of SDM, but a definition of SDM and SDM interventions is lacking detail in the evidence summary as well as the evidence report. Charles 1997 is cited and later Makoul 2006, both of whom have slightly different definitions of SDM. What about Whitney 2004 who differentiates SDM from informed decision making and informed consent? What about Elwyn, Frosch, etc. recent definition of SDM and decision support interventions? Or Elwyn's IPDASi checklist? This is very important to define for readers to better understand the context of the review and to better understand whether key SDM interventions are missing from the review. | Thank you for the suggestion. We made the requested edit throughout the report. We added a detailed section on SDM and SDM interventions (pg 12-14), including the scope of our review including definitions, purpose, evidence-based framework utilized (ODSF) (pg 13 paragraph 3; pg 14, paragraph 1), and inclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5). It should now be clearer why some key decision aid studies were excluded. Additionally, we prepared a table of excluded studies (Appendix B) The reviewer makes a valid point. We edited this sentence (pg 4 paragraph 2) and added context for the interventions throughout the executive summary to improve the clarity.
The authors should specifically refer to the context for their findings when discussing them. For example, line 18, p. 3, should say “whether to be screened for breast cancer…” (the words “for breast cancer” are missing and then it is unclear if it is for another cancer such as CRC). Please check throughout. Some word choice is unclear. E.g. p. 1, line 15, “policy SDM needs…” policy doesn't have needs. SDM interventions could have policy implications but patient and clinical needs are separate from policy implications. This part needs rewording. | Thank you for the suggestion. We made the requested edit throughout the report. Thank you for the suggestion. We reworded this section (pg 1 paragraph 1).
Yes. The objectives, scope, and methods are generally well described. Although SDM is defined, there are no explicit criteria that I could find for interventions that are considered SDM interventions. For example, was a criterion for inclusion of a study to have an intervention with an explicit component to encourage collaborative or shared decision making with the clinician (such as coaching patients to speak with their clinician about the decision or the timing of an intervention prior to a clinician visit)? Was the search limited to decision-aids or did it include other interventions that support SDM but may not have incorporated all of the components of a decision aid? Did the investigators seek to identify whether studies documented the occurrence of shared decision-making (through, for example, audio-recordings of the doctor patient interaction or patient self-report of shared decision making)? Or, did the investigators assume that if an intervention was designed with the goal of supporting shared decision-making that shared decision-making occurred? These points highlight the distinction between a review of decision-aid studies and a review of studies designed to support SDM. | Thank you. We added a detailed section on SDM and SDM interventions (pg 12-14), including the scope of our review including definitions, purpose, evidence-based framework utilized (ODSF) (pg 13 paragraph 3; pg 14, paragraph 1), and inclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5).
Yes | Thank you
No. Reading this report makes me appreciate how difficult this topic was to review. The purpose of engaging in shared decision making is not really clearly stated – page 1, line 13 says it's to “improve clinical care” but is the desired outcome to encourage patients to get recommended cancer screening tests or to discourage inappropriate ones or to help them make choices that they're happy with, regardless of whether the healthcare team considers them “right” or “wrong”? Is there evidence that patients aren't making the “best” decisions? The report makes me realize that the whole concept of SDM assumes that people make rational decisions when presented with the evidence and an opportunity to think it through (values clarification, etc.) but what if that's not how most people make their decisions? Is it okay for the labeling of a decision as “preference sensitive” to be done by healthcare professionals, rather than by patients? I think so, but perhaps a comment about that should be included. The Ottawa Decision Support Framework is mentioned as the framework used but is not described or explained as to why it was chosen. Some of the studies reviewed seem to have used DAs as stand-alone interventions with patients, without “sharing” the decision with a healthcare provider, even though SDM is described as involving both. For example, the two breast cancer screening SDM trials described on pages 22-23 both involved providing participants with a DA but don't mention discussion of their screening decisions with their healthcare providers. Perhaps these studies are better described as “informed decision making.” | We added a detailed section on SDM and SDM interventions (pg 12-14), including the scope of our review including definitions, purpose, evidence-based framework utilized (ODSF) (pg 13-14). We added detailed information on the Ottawa Decision Support Framework, and how it guided our review, (pg 13 paragraph 3, pg 14 paragraph 1). Facilitating informed decision making could be a stand-alone strategy for facilitating the broader goal of SDM, or could be one component of a multi-faceted SDM intervention. We do not exclude SDM interventions restricted to informed decision making processes from the review. We added a detailed section on SDM, and SDM interventions (pg 12-14). Hopefully it is clearer how we conceptualized SDM interventions, and the scope of our review.
The multiple outcomes measured (components of Decision Quality, Decision Impact, and Decision Action) seem to be closely related and a bit hard to differentiate at times. Are they all of equal importance? In the Conclusions paragraph (page 45, lines 31-33), it'd be helpful to say what effect on Decision Quality and Impact would have been expected/ desired from SDM. I assume they should ideally have increased but I'm not sure. | As specified in our revised background section and description of the Ottawa Decision Making Framework, measures of the decision making process (i.e., decision quality and decision impact) receive priority over decision action in selecting studies. We excluded studies that only examined decision action outcomes. In both the Executive Summary and the main report we discuss ideal cancer screening SDM intervention outcomes in SDM interventions (e.g., decrease decisional conflict, increase patient satisfaction, increase knowledge) (pg 1 paragraph 2; pg 13 paragraph 3).
No. The objectives, scope, and methods are mostly described well. One exception is that I am unclear by your use of the term SDM interventions. You don't really define it and it's a term commonly used in the literature. I assume you are referring to decision aids and decision support interventions (which becomes clear after the executive summary I am not sure why you are using that term but given its lack of use in the literature you should define it and give examples of what you mean (both in the executive summary and in the main document). Click here to enter text. Also, it may be beneficial to describe a little better the measures used in the studies. | We added a detailed section on SDM and SDM interventions (pg 12-14). We prepared a table describing the measures used in the included studies (Appendix E).
Yes. The methods are clearly described. The division into decision quality, decision impact, and decision action doesn't work very well for me but is clearly described. | Thank you
2. Is there any indication of bias in our synthesis of the evidence?
No | Thank you
I am not sure why authors excluded those studies looking at decision action alone. It isn't clear why they chose to include studies that included all three types of outcomes (decision action, decision quality, and decision impact). I would include studies that assessed *any* of the outcomes and just report on those outcomes with slightly different Ns in each. Otherwise they exclude quite a few studies that might be relevant (starting with 2368 hits, going down to 22 unique trials). I now see in the limitations section that the authors state they excluded studies looking at decision action alone because they didn't want to include studies encouraging screening, but with a clear definition of SDM this can be mitigated rather than excluding potentially relevant SDM interventions just because of choice of outcome measures. I am also not sure why authors excluded studies in settings other than primary care or studies in non-clinical settings. This needs clarification. | We added a detailed section on SDM and SDM interventions (pg 12-14), including the scope of our review including definitions, purpose, evidence-based framework utilized (ODSF) (pg 13 paragraph 3; pg 14 paragraph 1), and inclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5). Additionally, we prepared a table of excluded studies (Appendix B). We clarified our inclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5); to be consistent with the definition guiding this review, which defines SDM as a process that involves interaction between patients and clinical providers, we sought to identify interventions implemented and evaluated in clinical settings where such a dialogue could possibly occur. Clinic settings, either at or shortly before an appointment, were a component to encourage SDM with the clinician.
Study selection in general does not match up with definitions of SDM. So did authors consider an intervention an “SDM intervention” only if it provided both risk and benefit information? What about values clarification? (p. 13, lines 23-29). This again leads back to clarifying what definition they are using. I am not sure whether the list of hand-searched journals is complete. What about BMJ or HEX, for example? | We selected studies based on the stated goals of the interventions and outcomes measured, rather than on content of the intervention per se. There are many ways to facilitate SDM and interventions that increase patient knowledge of risks and benefits, even without explicit values clarification are still SDM interventions. We added a detailed section on SDM and SDM interventions (pg 12-14), and inclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5), We hope it is now clearer why we included the studies. A complete list of hand-searched journals (including British Medical Journal and Health Expectations) is provided in the Methods section (pg 16 paragraph 3).
No | Thank you
Yes. The appearance of bias comes from uncertainty in the threshold to conclude SDM interventions for cancer screening do more good than harm. The review notes in Executive Summary Table 1 that 18/19 trials show improved knowledge. If one believes in truly informed consent for screening tests (and national guidelines certainly stress that point, particularly for prostate cancer screening), isn't that the key outcome? In addition, 3/6 trials show an increase in values clarity, 7/13 show a reduction in decisional conflict, 3/6 show reduced use of services, and 1/2 show an increase in decision satisfaction. Moreover, among the prostate trials, 5/9 show a reduction in screening intention, and 7/12 show a reduction in screening test use. These results seem more impressive than the tone of the discussion in the paper suggests, particularly as there seems to be little evidence of harm. | The reviewer makes a valid point. In the discussion we made an effort to emphasize that SDM interventions for cancer screening did more good than harm, while accurately presenting the state of the evidence (pg 49 paragraph 2).
No. | Thank you
No. More details on your search terms is necessary (perhaps also include in exec summary—found them in main body). I was surprised that none of the following were search terms: decision aids, decision support interventions, patient education, shared decision making. | We added more information about our search in the review (pg 16 paragraphs 2-3) and executive summary (pg 2 paragraph 2) and clarified that the mentioned terms were included. These terms are also presented in Appendix A.
No. | Thank you
3. Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
Yes. Taylor KL, et al. Decision making in prostate cancer screening using decision aids vs. usual care: a randomized clinical trial. JAMA Intern Med 2013;173:1704. | Thank you for this suggestion. We agreed that this study was overlooked and we included it in the revised report.
Yes. What about Jane Kim et al. 2004 BMC Medical Informatics and Decision Making, 5:36, and Carmen Lewis et al. 2010 BMC Medical Informatics and Decision Making (both about colorectal cancer screening decision aids). For decision aids specifically, why not look at the Cochrane Review and then look for RCTs of cancer screening decision aids? Can the authors search Dawn Stacey's review of decision aids for cancer specifically (in CA: A Cancer Journal for Clinicians)? | Thank you for these suggestions. These articles were assessed and excluded during our search; we added more information about our exclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5), and we prepared a table of excluded studies (Appendix B).We did use the Cochrane Review, Dr. Stacey's review, as well as others as part of search strategy to identify relevant studies.
No. Not that I am aware of. | Thank you
No. | Thank you
Yes. There are many studies of decision aids not included in the review – perhaps appropriately, but it's not always clear why some were and some weren't | We added more information about our exclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5), and we prepared a table of excluded studies (Appendix B).
Dawn Stacey's 2014 Cochrane review of decision aids, Mara Schonberg's 2014 JAMA: IM article on a screening decision aid for women > 75. Maybe John Inadomi's 2012 JAMA: IM article. Sarah Hawley has finished 2 studies looking at CRC screening interventions (one in the VA). Frosch, Legare, Mangione 2008, patient education and counseling (screening in ethnically diverse clinics). Lin et al health Affairs 2013 vol. 32no. 2 311-320 | Thank you for these suggestions. We used Dr. Stacey's review in our search strategy to identify relevant articles and these articles were assessed and excluded during our search; we added more information about our exclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5), and we prepared a table of excluded studies (Appendix B).We were unable to include Dr. Hawley's studies as they were unpublished as of July, 2014.
Yes. The decision to not include the studies that focus only on decision action doesn't make sense to me, if you want to make conclusions about that set of outcomes. | We aimed to review studies that evaluated the decision making process. Studies that focused on Decision Action did not fit this criterion and were excluded, as well as interventions that promoted screening. We added more information about our exclusion criteria (pg 14 paragraph 1; pg 16 paragraph 5), and we prepared a table of excluded studies (Appendix B).
4. Please write any additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
P 1, line 22: Typo: Should read that decision quality is characterized by knowledge, value-concordance, and patient role. P 1, line 30: Would suggest just using the phrase “intervention target,” the system/organization does not seem to be a population. P 3, lines 4-5 (and elsewhere [KQ3]): Would clarify whether results are from lack of effectiveness and/or insufficient sample size. P 10, line 41. USPSTF does not consider barium enema as an acceptable test; would delete or add CT colonography. P 24, line 30: CRC screening is also effective in reducing cancer-related mortality and cancer incidence. P 37, line 36-8: Which intervention (booklet or pamphlet) was favored for these outcomes? P 42, line 10: Typo. Should read “decreased their intention to order PSA” | Thank you for the suggestions. We made this edit (pg 1 paragraph 2). We agree with the reviewer and made the requested edit throughout the report. The reviewer makes a valid point and we clarified this throughout the report. We made this edit (pg 13 paragraph 1). We made this edit (pg 27 paragraph 1). We edited the comparative effectiveness trials section to clarify which interventions were favored (pg 32 paragraph 3 – pg 33 paragraph 3) We clarified that the intervention group had a lower intention to order PSA (pg 47 paragraph 2; pg 6 paragraph 3)
Line 14, p. 35: the highest standard in risk communication is not necessarily pictographs…I would rephrase. Newer research suggests bar graphs might be ok, and the most important standard is to use frequencies or percentages rather than RR, AR, NNT, etc. Also see Fagerlin et al 2011, JNCI, 10 steps to better risk communication, for a more recent reference. Although there is no evidence that more resource intensive SDM interventions do better than less resource intensive SDM interventions, few studies assessed this. I would clarify that throughout the review as it has clear policy implications and it might be premature to say a pamphlet (that might not be read by everyone in standard practice vs. in the context of a voluntary research study) does better than other interventions. Could be added to the conclusions section. In general the conclusions are well written and clear. | Thank you for this suggestion. We rephrased to reflect the most current research and included Fagerlin et al 2011 (pg 39 paragraph 2). We agree and we clarified throughout the report that conclusions should not be drawn from a single study. Thank you
There is an error in line 21 when Decision Quality is defined using the same outcomes as Decisional Impact. | We made the requested edit (pg 1 paragraph 2).
In the analyses of decision action for SDM interventions for prostate cancer screening, the heterogeneity and differential effects among studies may reflect confounding by the baseline rate. In theory, whether decision action changes and in what direction might depend on whether PSA screening at baseline was overutilized or underutilized. Can the results be stratified based on testing rates in the control group, perhaps comparing the mean baseline rates in the control group for the 7 studies showing a drop in utilization with SDM, versus the 5 showing no effect? | There is a limited range in PSA rates across the prostate cancer studies; the range of mean PSA screening rates is narrow, and thus stratifying would not be a productive.
Page 1, lines 21-22: text in the parentheses after Decision Quality and Decision Impact is repeated. Page 10, lines 14-16: the sentence starting “SDM involves…” could be better written as “SDM involves integrating the knowledge of health care professionals and the values and preferences of patients to arrive at a final decision.” Page 10, line 20: please consider (here and throughout) using the word “use” or “used” rather than “utilization” or “utilized” Page 17, lines 25: the definition of “attention control” trials is not provided here, when the term is first used. Page 18, Table 1: it's not clear what the “0” means in this table. Does it mean no effect or not studied or something else? Page 24, line 8: are the percents listed (95.5% and 9.3%) correct? They're described as showing no effect between the 2 groups. Page 31, line 20: refer the reader to Appendix C, Table 1 to understand how the risk of bias was determined | We made this edit (pg 1 paragraph 2). Thank you for the suggestion. We reworded this paragraph (pg 11 paragraph 1). We agree with the reviewer's suggestion and made the requested clarifications throughout the report. We added a definition of ‘attention control trials’ (pg 21 paragraph 1). The ‘0’ referred to no effect. However, we made this table consistent with others and added foot notes to all tables. The percentages from Mathieu 2007 (9.5% and 9.3%) can be found in Table 4 (pg 76); the text now reads “Mathieu 2007 also measured screening outcomes one month post-intervention and found that SDM had no effect on having made or planning to make a mammography appointment” (pg 26 paragraph 4). Thank you for the suggestion. Strength of Evidence and Risk of Bias are described fully in the methods and separately in the results. We added a reference to Appendix F (pg 45 paragraph 2).
The executive summary is hard to understand without context. For example: “A single SDM intervention designed to facilitate decisions about whether women who are younger or older than typically recommended for breast cancer screening should be screened had no effect on decisional conflict.” What was the intervention? Executive summary table #2: How were these ratings done? Hard to evaluate the table. You discuss the methods in the main body, so maybe just not include the table in the ES unless you provide some detail there. Another area that needs more research is how to get SDM interventions/decision aid implemented into clinical practice. Often research finds them beneficial in a variety of ways, but once the research staff is no longer engaged (i.e., the research is done), the decision aids never get to patients. How can that change? On page 41 you write: Given the large body of research outlining the most effective ways to communicate risk and decision making theory, it is possible that authors did not report this information. I think you are optimistic. Granted it was 10 years ago, but Fagerlin et al's review of prostate cancer treatment decision aids found that few included any numerical information at all. We are currently reviewing cancer screening guidelines and you would be stunned by the number that don't include numbers (particularly for benefit of screening). When discussing previous reviews, you do not cite Stacey et al 2014 Cochrane review of decision aids or the most recent updating of the IPDAS guidelines which will be valuable to you: http://www.biomedcentral.com/bmcmedinformdecismak/supplements/13/S2 | The reviewer makes a valid point. We rewrote the executive summary to improve its clarity throughout and added context for interventions. The reviewer makes a valid point. To improve readability of the Executive Summary, we removed the complete evidence table and included this in the main body where we explained our ratings methods. The reviewer brings up an interesting point. We addressed implementation challenges in the discussion, citing Dr. Gravel's 2006 review (pg 48 paragraph 3). We tempered our optimism and cited the Fagerlin et al review (pg 39 paragraph 2). We look forward to reading the upcoming review of cancer screening guidelines. Thank you for the suggestion We included the most recent Cochrane review in our discussion of previous reviews (pg 48 paragraph 2) and discuss IPDAS guidelines in our introduction (pg 13 paragraph 3). We did use these resources reports in our search strategy, but this was not made clear in our report. We have clarified this in the revised report, and added more information about our search strategy (pg 16 paragraphs 2-3).
Page 10, lines 32-34 – I think this should be “mortality” rather than “morbidity”; I would say the benefits and harms are closely balanced and that the decision is preference-sensitive (not the balance) My only other comment is that the text descriptions of the individual studies are long and somewhat hard to read- better to use the tables to convey that information. | Thank you for the suggestions. In the course of our edits this sentence was deleted. We reworded the section the reviewer referred to. Thank you for the suggestion. We edited the text descriptions of the individual studies slightly and directed the reader to evidence tables (Appendix D).
5. Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
Could identify available VA decision support tools (either developed by VA or accessible through CPRS); for example, the recently developed VA decision tool for prostate cancer screening. | We discussed VA-developed decision support tools, both currently available and potential in the future (pg 49 paragraphs 1-2).
The report does a good job of highlighting the need for additional studies in lung and cervical cancer and for studies that have a clinician-intervention component | Thank you
Given the mostly low-quality evidence, it'd be helpful to say what should be done at present, if anything, about using SDM for cancer screening. | We added additional suggestions and commentary about how to use SDM in cancer screening, despite the quality of evidence (pg 53 paragraph 3).
It may be useful to discuss implementation issues outside of cancer screening. Please see France Legare's and Dominick Frosch's work | Thank you for the suggestion. In our discussion we addressed implementation challenges, citing Dr. Gravel's 2006 review (of which Dr. Légaré is a co-author) (pg 53 paragraph 3).