# EXCLUDED ARTICLES

Study | Reason for exclusion | Reference
Adab 2003 | Decision Action outcome only | Adab P, Marshall T, Rouse A, Randhawa B, Sangha H, Bhangoo N. Randomised controlled trial of the effect of evidence based information on women's willingness to participate in cervical cancer screening. J Epidemiol Comm Health. 2003;57(8):589-93.
Agrez 1998 | Not RCT | Agrez MV, Coory M, Cockburn J. Population screening for colorectal carcinoma with fecal-occult blood testing: are we sufficiently informed? Cancer. 1998;82(10):1803-7.
Allen 2010 | Non-clinic setting | Allen JD, Othus MK, Hart A Jr, et al. A randomized trial of a computer-tailored decision aid to improve prostate cancer screening decisions: results from the Take the Wheel trial. Cancer Epidemiol Biomarkers Prev. 2010;19(9):2172-86.
Auvinen 2001 | Not cancer screening | Auvinen A, Vornanen T, Tammela TL, et al. A randomized trial of the choice of treatment in prostate cancer: design and baseline characteristics. BJU Int. 2001;88(7):708-15.
Banks 2014 | Not cancer screening | Banks J, Hollinghurst S, Bigwood L, Peters TJ, Walter FM, Hamilton W. Preferences for cancer investigation: a vignette-based study of primary-care attendees. Lancet Oncol. 2014;15(2):232-40.
Berry 2013 | Not cancer screening | Berry DL, et al. The Personal Patient Profile-Prostate decision support for men with localized prostate cancer: A multi-center randomized trial. Urol Oncol. 2013; 31(7):1012-1021
Chan 2011 | Non-clinic setting | Chan EC, et al. A community-based intervention to promote informed decision making for prostate cancer screening among Hispanic American men changed knowledge and role preferences: a cluster RCT. Patient Educ Couns. 2011;84(2):e44-51.
Christy 2013 | Screening promotion | Christy SM, et al. Promoting colorectal cancer screening discussion: a randomized controlled trial. Am J Prev Med. 2013;44(4):325-9.
Costanza 2011 | Not RCT | Costanza ME, Luckmann RS, Rosal M, et al. Helping men make an informed decision about prostate cancer screening: a pilot study of telephone counseling. Patient Educ Couns. 2011;82(2):193–200.
Davis 2013 | Not RCT | Davis TC, et al. Contrasts in Rural and Urban Barriers to Colorectal Cancer Screening. Am J Health Behav. 2013; 37(3):289-298
Dolan 2005 | Not RCT (secondary observational study from included Dolan 2002) | Dolan JG. Patient priorities in colorectal cancer screening decisions. Health Expect. 2005;8(4):334-44.
Dorfman 2010 | Not RCT (development/usability testing for included Taylor 2013) | Dorfman CS, et al. The development of a web- and a print-based decision aid for prostate cancer screening. BMC Med Inform Decis Mak. 2010;10:12.
Driscoll 2008 | Non-clinic setting | Driscoll DL, Rupert DJ, Golin CE, McCormack LA, Sheridan SL, Welch BM. Promoting prostate-specific antigen informed decision-making. Evaluating two community-level interventions. Am J Prev Med. 2008;35(2):87–94.
Edwards 2013 | Not RCT | Edwards AGK, et al. Personalised risk communication for informed decision making about taking screening tests. Cochrane Database Syst Rev. 2013. 2: CD001865.
Edwards 2006 | Not RCT | Edwards AGK, et al. Personalised risk communication for informed decision making about taking screening tests. Cochrane Database Syst Rev. 2006(4): CD001865.
Edwards 2003 | Not RCT | Edwards A, et al. Personalised risk communication for informed decision making about entering screening programs. Cochrane Database Syst Rev. 2003(1): CD001865.
Ellison 2008 | Non-clinic setting | Ellison GL, Weinrich SP, Lou M, Xu H, Powell IJ, Baquet CR. A randomized trial comparing web-based decision aids on prostate cancer knowledge for African-American men. J Natl Med Assoc. 2008;100(10):1139- 45.
Elwyn 2012 | Not RCT | Elwyn G, Rix A, Holt T,et al. Why do clinicians not refer patients to online decision support tool? Interviews with front line clinics in the NHS. BMJ Open. 2012; 2
Evans 2007 | Not RCT (protocol for included Evans 2010) | Evans R, et al. A randomised controlled trial of the effects of a web-based PSA decision aid, Prosdex. Protocol. BMC Fam Pract. 2007;8:58
Feldman-Stewart 2012 | Not cancer screening | Feldman-Stewart D, Tong C, Siemens R, et al. The impact of explicit values clarification exercises in a patient decision aid emerges after the decision is actually made: evidence from a randomized controlled trial. Med Decis Making. 2012;32(4):616-26.
Feng 2013 | Not RCT | Feng B, Srinivasan M, Hoffman JR, et al. Physician communication regarding prostate cancer screening: analysis of unannounced standardized patient visits. Ann Fam Med. 2013;11(4):315-23.
Flight 2012 | Non-clinic setting | Flight IH, Wilson CJ, Zajac IT, Hart E, McGillivray JA. Decision Support and the Effectiveness of Web-based Delivery and Information Tailoring for Bowel Cancer Screening: An Exploratory Study. JMIR Res Protoc. 2012;1(2):e12.
Frosch 2008 | Not RCT | Frosch DL, Légaré F, Mangione CM. Using decision aids in community-based primary care: a theory-driven evaluation with ethnically diverse patients. Patient Educ Couns. 2008;73(3):490-6.
Frosch 2001 | Not RCT | Frosch DL, Kaplan RM, Felitti V. Evaluation of two methods to facilitate shared decision making for men considering the prostate-specific antigen test. J Gen Intern Med. 2001;16(6):391–8.
Flood 1996 | Not RCT | Flood AB, et al. The importance of patient preference in the decision to screen for prostate cancer. Prostate Patient Outcomes Research Team. J Gen Intern Med. 1996;11(6):342-9.
Gattellari 2005 | Non-clinic setting | Gattellari M, Ward JE. A community-based randomised controlled trial of three different educational resources for men about prostate cancer screening. Patient Educ Couns. 2005;57(2):168-82.
Griffith 2008 | Non-clinic setting | Griffith JM, Lewis CL, Brenner AR, Pignone MP. The effect of offering different numbers of colorectal cancer screening test options in a decision aid: a pilot randomized trial. BMC Med Inform Decis Mak. 2008;8:4.
Griffith 2008 | Not RCT | Griffith JM, Fichter M, Fowler FJ, Lewis C, Pignone MP. Should a colon cancer screening decision aid include the option of no testing? A comparative trial of two decision aids. BMC Med Inform Decis Mak. 2008;8:10.
Hall 2011 | Not cancer screening | Hall MJ, et al. Effects of a decision support intervention on decisional conflict associated with microsatellite instability testing. Cancer Epidemiol Biomarkers Prev. 2011; 20(2):249-54.
Han 2013 | Not RCT | Han PKJ, et al. National Evidence on the Use of Shared Decision Making in Prostate-Specific Antigen Screening. Ann Fam Med. 2013; 11(4) 360-314
Hayat Roshanai 2013 | Not RCT | Hayat Roshanai A, Nordin K, Berglund G. Factors influencing primary care physicians' decision to order prostate-specific antigen (PSA) test for men without prostate cancer. Acta Oncol. 2013; 52(8):1602-1608.
Hayes 2014 | Not RCT | Hayes JH, Barry MJ. Screening for Prostate Cancer With the Prostate Specific Antigen Test A Review of Current Evidence. JAMA. 2014; 311(11):1143-1149.
Holloway 2003 | Screening promotion | Holloway RM, et al. Cluster-randomised trial of risk communication to enhance informed uptake of cervical screening. Br J Gen Pract. 2003. 53(493):620-5.
Hooker 2011 | Not cancer screening | Hooker GW, et al. Longitudinal changes in patient distress following interactive decision aid use among BRCA1/2 carriers: a randomized trial. Med Decis Making. 2011; 31(3):412-21
Ilic 2008 | Non-clinic setting | Ilic D, Egberts K, McKenzie JE, Risbridger G, Green S. Informing Men about Prostate Cancer Screening: A Randomized Controlled Trial of Patient Education Materials. J Gen Intern Med. 2007; 23(4): 466-471.
Inadomi 2012 | Screening promotion | Inadomi JM, Vijan S, Janz NK, et al. Adherence to colorectal cancer screening: a randomized clinical trial of competing strategies. Arch Intern Med. 2012;172(7):575-82.
Jerant 2013 | Not RCT (secondary study from unpublished RCT) | Jerant A,, et al. Effects of Tailored Knowledge Enhancement on Colorectal Cancer Screening Preference across Ethnic and Language Groups. Patient Edu Couns. 2013;90(1):103-110
Jerant 2007 | Screening promotion | Jerant A, Kravitz RL, Rooney M, Amerson S, Kreuter M, Franks P. Effects of a tailored interactive multimedia computer program on determinants of colorectal cancer screening: a randomized controlled pilot study in physician offices. Patient Educ Couns. 2007;66(1):67–74.
Joseph-Williams 2010 | Not RCT (secondary observational study from included Evans 2010) | Joseph-Williams N, et al. Supporting informed decision making online in 20 minutes: an observational web-log study of a PSA test decision aid. J Med Internet Res. 2010; 12(2):e15
Kassan 2012 | Not RCT (secondary observational study from included Taylor 2013) | Kassan EC, et al. Men's use of an Internet-based decision aid for prostate cancer screening. J Health Commun. 2012;17(6):677-97.
Katsumura 2008 | Not RCT | Katsumura Y, Yasunaga H, Imamura T, Ohe K, Oyama H. Relationship between risk information on total colonoscopy and patient preferences for colorectal cancer screening options: analysis using the analytic hierarchy process. BMC Health Serv Res. 2008; 8:106
Kerns 2008 | Not RCT (secondary observational study from included Krist 2007) | Kerns JW, Krist AH, Woolf SH, Flores SK, Johnson RE. Patient perceptions of how physicians communicate during prostate cancer screening discussions: a comparison of residents and faculty. Fam Med. 2008;40(3):181-7.
Kim 2005 | Not RCT | Kim J, Whitney A, Hayter S, et al. Development and initial testing of a computer-based patient decision aid to promote colorectal cancer screening for primary care practice. BMC Med Inform Decis Mak. 2005;5:36.
Korfage 2013 | Not cancer screening | Korfage IJ, Fuhrel-Forbis A, Ubel PA, et al. Informed choice about breast cancer prevention: randomized controlled trial of an online decision aid intervention. Breast Cancer Res. 2013;15(5):R74.
Krist 2007 | Not RCT (secondary observational study from included Krist 2007) | Krist AH, Woolf SH, Johnson RE. How physicians approach prostate cancer screening before and after losing a lawsuit. Ann Fam Med. 2007;5(2):120-5.
Lairson 2011 | Screening promotion | Lairson DR, Chan W, Chang YC, del Junco DJ, Vernon SW. Cost-effectiveness of targeted versus tailored interventions to promote mammography screening among women military veterans in the United States. Eval Program Plann. 2011;34(2):97–104.
Lawrence 2000 | Not RCT | Lawrence VA, Streiner D, Hazuda HP, Naylor R, Levine M, Gafni A. A cross-cultural consumer-based decision aid for screening mammography. Prev Med. 2000;30(3):200-8.
Leader 2012 | Not RCT (secondary observational study from included Myers 2011) | Leader A, Constantine Daskalakis C, Braddock III CH, et al. Measuring Informed Decision Making about Prostate Cancer Screening in Primary Care. Med Decis Making. 2012; 32(2): 327-36.
Legare 2010 | Not RCT | Legare F. Ratte S, Stacey D, Kryworuchko J, Gravel K, Graham ID, Turcotte S. Interventions for improving the adoption of shared decision making by healthcare professionals. Cochrane Database Syst Rev. 2010;12(5):CD006732
Lerman 1997 | Not cancer screening | Lerman C, et al. Controlled trial of pretest education approaches to enhance informed decision-making for BRCA1 gene testing. J Natl Cancer Inst. 1997; 89(2):148-57.
Lewis 2012 | Screening promotion | Lewis CL, Brenner AT, Griffith JM, Moore CG, Pignone MP. Two controlled trials to determine the effectiveness of a mailed intervention to increase colon cancer screening. N C Med J. 2012;73(2):93-8.
Lewis 2010 | Not RCT | Lewis CL, Golin CE, DeLeon C, et al. A targeted decision aid for the elderly to decide whether to undergo colorectal cancer screening: development and results of an uncontrolled trial. BMC Med Inform Decis Mak. 2010;10:54.
Lewis 2010 | Not RCT | Lewis CL, Pignone MP, Schild L, et al. Effectiveness of a patient and practice-level colorectal cancer screening intervention in health plan members: design and baseline findings of the CHOICE trial. Cancer. 2010;116(7):1664–73.
Lin 2013 | Not RCT | Lin GA, Halley M, Rendle KA, et al. An effort to spread decision aids in five California primary care practices yielded low distribution, highlighting hurdles. Health Aff (Millwood). 2013;32(2):311-20.
Linder 2011 | Not RCT (secondary psychometric study from included Volk 2008) | Linder SK, Swank PR, Vernon SW, Mullen PD, Morgan RO, Volk RJ. Validity of a low literacy version of the Decisional Conflict Scale. Patient Edu Couns. 2011; 85:521-524
Lindbloom 2012 | Non-clinic setting | Lindblom K, Gregory T, Wilson C, Flight IH, Zajac I. The impact of computer self-efficacy, computer anxiety, and perceived usability and acceptability on the efficacy of a decision support tool for colorectal cancer screening. J Am Med Inform Assoc. 2012;19(3):407-412.
McCormack 2011 | Non-clinic setting | McCormack L, Treiman K, Bann C, et al. Translating medical evidence to promote informed health care decisions. Health Serv Res. 2011;46(4):1200-23.
Miller 2011 | Screening promotion | Miller DP, Spangler JG, Case D, Goff DC, Singh S, Pignone M. Effectiveness of a Web-Based Colorectal Cancer Screening Patient Decision Aid: A Randomized Controlled Trial in a Mixed-Literacy Population. Am J Prev Med. 2011; 40(6):608-615.
The Multicentre Australian Colorectal neoplasia Screening Group 2006 | Non-clinic setting | Multicentre Australian Colorectal-neoplasia Screening Group. A comparison of colorectal neoplasia screening tests: a multicentre community-based study of the impact of consumer choice. Med J Aust 2006;184(11):546- 50.
Murphy 2014 | Not RCT | Murphy DG, et al. The Melbourne Consensus Statement on the early detection of prostate cancer. BJU Int. 2014; 113:186-188
Myers 2011 | Not cancer screening | Myers RE, et al. A randomized trial of genetic and environmental risk assessment (GERA) for colorectal cancer risk in primary care: trial design and baseline findings. Contemp Clin Trials. 2011;32(1):25-31.
Myers 2007 | Screening promotion | Myers RE, Sifri R, Hyslop T, et al. A randomized controlled trial of the impact of targeted and tailored interventions on colorectal cancer screening. Cancer. 2007;110(9):2083–91.
Myers 2005 | Decision Action outcome only | Myers RE, et al. Preparing African-American men in community primary care practices to decide whether or not to have prostate cancer screening. J Natl Med Assoc. 2005;97(8): 1143-54.
Myers 2005 | Not RCT | Myers RE. Decision counseling in cancer prevention and control. Health Psychol. 2005;24(4 Suppl):S71–7.
Myers 1999 | Decision Action outcome only | Myers RE, et al. Adherence by African American men to prostate cancer education and early detection. Cancer. 1999;86(1):88-104.
Nijs 1997 | Non-clinic setting | Nijs HG, Tordoir DM, Schuurman JH, Kirkels WJ, Schröder FH. Randomised trial of prostate cancer screening in The Netherlands: assessment of acceptance and motives for attendance. J Med Screen. 1997;4(2):102-6.
O'Brien 2010 | Screening promotion | O'Brien MJ, Halbert CH, Bixby R, Pimentel S, Shea JA. Community health worker intervention to decrease cervical cancer disparities in Hispanic women. J Gen Intern Med. 2010;25(11):1186-92.
O'Neill 2010 | Not cancer screening | O'Neill SC, et al. BRCA1/2 test results impact risk management attitudes, intentions, and uptake. Breast Cancer Res Treat. 2010;124(3):755-64.
Pace 2014 | Not RCT | Pace LE, Keating NL. A systematic assessment of benefits and risks to guide breast cancer screening decisions. JAMA. 2014;311(13):1327-35.
Park 2005 | Screening promotion | Park S, Chang S, Chung C. Effects of a cognition-emotion focused program to increase public participation in Papanicolaou smear screening. Public Health Nurs. 2005;22(4):289-98.
Perneger 2011 | Non-clinic setting | Perneger TV, Schiesari L, Cullati S, Charvet-Bérard A. Does information about risks and benefits improve the decision-making process in cancer screening - randomized study. Cancer Epidemiol. 2011; 35(6):574-9.
Pignone 2013 | Non-clinic setting | Pignone MP, et al. Comparing 3 techniques for eliciting patient values for decision making about prostate-specific antigen screening: a randomized controlled trial. JAMA Intern Med. 2013;173(5):362-8.
Pignone 2012 | Non-clinic setting | Pignone MP, Brenner AT, Hawley ST, et al. Conjoint analysis versus rating and ranking for values elicitation and clarification in colorectal cancer screening. J Gen Intern Med. 2012; 27(1):45–50.
Pignone 2011 | Not RCT | Pignone MP, Winquist A, Schild L, et al. Effectiveness of a patient and practice-level colorectal cancer screening intervention in health plan members. Cancer. 2011;117(15):3252–62.
Pignone 2000 | Decision Action outcome only | Pignone M, Harris R, Kinsinger L. Videotape-based decision aid for colon cancer screening. A randomized, controlled trial. Ann Intern Med. 2000;133(10): 761-9.
Price-Haywood 2014 | Screening promotion | Price-Haywood EG, Harden-Barrios J, Cooper LA. Comparative effectiveness of audit-feedback versus additional physician communication training to improve cancer screening for patients with limited health literacy. J Gen Intern Med. 2014; 29(8):1113-21.
Price-Haywood 2010 | Not RCT (baseline assessments from Price-Haywood 2014) | Price-Haywood E, Roth KG, Shelby K, Cooper LA. Cancer Risk Communication with Low Health Literacy Patient: A Continuing Medical Education Program. J Gen Intern Med. 2010; 25(2): 126-129
Rimer 2001 | Screening promotion | Rimer BK, et al. The short-term impact of tailored mammography decision-making interventions. Patient Educ Couns. 2001;43(3): 269-85.
Rimer 2002 | Screening promotion | Rimer BK, et al. Effects of a mammography decision-making intervention at 12 and 24 months. Am J Prev Med. 2002;22(4):247-57.
Rubel 2010 | Non-clinic setting | Rubel SK, et al. Testing the effects of a decision aid for prostate cancer screening. J Health Comm. 2010;15(3):307-21.
Ruffin 2007 | Screening promotion | Ruffin MT 4th, Fetters MD, Jimbo M. Preference-based electronic decision aid to promote colorectal cancer screening: results of a randomized controlled trial. Prev Med. 2007;45(4):267-73.
Schoenberg 2013 | Not RCT | Schoenberg MA, Hamel MB, Davis RB, et al. Development and evaluation of a decision aid on mammography screening for women 75 and older. JAMA Intern Med. 2013;174(3):417-24.
Schroy 2011 | Not RCT | Schroy PC 3rd, Mylvaganam S, Davidson P. Provider perspectives on the utility of a colorectal cancer screening decision aid for facilitating shared decision making. Health Expect. 2011;17(1):27-35.
Sheridan 2004 | Not RCT | Sheridan SL, Felix K, Pignone MP, Lewis CL. Information needs of men regarding prostate cancer screening and the effect of a brief decision aid. Patient Educ Couns. 2004;54(3):345–51.
Smith 2014 | Non-clinic setting | Smith SK, Simpson JM, Trevena LJ, McCaffery KJ. Factors Associated with Informed Decisions and Participation in Bowel Cancer Screening among Adults with Lower Education and Literacy. Med Decis Making. 2014;34(6):756-72.
Smith 2013 | Not RCT (discussion paper based on Smith 2010) | Smith SK, Nutbeam D, McCaffery KJ. Insights into the concept and measurement of health literacy from a study of shared decision making in a low literacy population. J Health Psychol. 2013; 18(8):1011–22.
Smith 2012 | Not RCT (secondary psychometric study from Smith 2010) | Smith SK, Barratt A, Trevena L, Simpson JM, Jansen J, McCaffery KJ. A theoretical framework for measuring knowledge in screening decision aid trials. Patient Educ Couns. 2012. 89(2):330-6.
Smith 2010 | Non-clinic setting | Smith SK, Trevena L, Simpson JM, Barratt A, Nutbeam D, McCaffery KJ. A decision aid to support informed choices about bowel cancer screening among adults with low education: randomised controlled trial. BMJ. 2010;341: c5370.
Stalmeier 2009 | Not cancer screening | Stalmeier PFM, Roosmalen MS. Concise evaluation of decision aids. Patient Educ Couns. 2009;74(1):104-9.
Stamatiou 2008 | Screening promotion | Stamatiou K, Skolarikos A, Heretis I, Papadimitriou V, Alevizos A, Ilias G, Karanasiou V, Mariolis A, Sofras F. Does educational printed material manage to change compliance with prostate cancer screening? World J Urol. 2008;26(4):365-73.
Steckelberg 2011 | Non-clinic setting | Steckelberg A, Hülfenhaus C, Haastert B, Mühlhauser I. Effect of evidence based risk information on “informed choice” in colorectal cancer screening: randomised controlled trial. BMJ. 2011;342:d3193.
Stephens 2008 | Not RCT | Stephens RL, Xu Y, Volk RJ, Scholl LE, Kamin SL, Holden EW. Influence of a patient decision aid on decisional conflict related to PSA testing: a structural equation model. Health Psychol. 2008;27(6):711–21.
Street 1998 | Screening promotion | Street RL Jr, Van Order A, Bramson R, Manning T. Preconsultation education promoting breast cancer screening: does the choice of media make a difference? J Cancer Educ. 1998;13(3):152-61.
Taylor 2006 | Non-clinic setting | Taylor KL, et al. Educating African American men about the prostate cancer screening dilemma: a randomized intervention. Cancer Epidemiol Biomarkers Prev. 2006;15(11):2179-88.
Tiller 2006 | Not cancer screening | Tiller K, Meiser B, Gaff C, et al. A randomized controlled trial of a decision aid for women at increased risk of ovarian cancer. Med Decis Making. 2006;26(4):360-72.
Valdez 2001 | Not RCT | Valdez A, Banerjee K, Fernandez M, Ackerson L. Impact of a multimedia breast cancer education intervention on use of mammography by low-income Latinas. J Cancer Educ. 2001;16(4):221–4.
van Roosmalen 2004 | Not cancer screening | van Roosmalen MS, et al. Randomized trial of a shared decision-making intervention consisting of trade-offs and individualized treatment information for BRCA1/2 mutation carriers. J Clin Oncol. 2004;22(16):3293-301.
van Roosmalen 2004 | Not cancer screening | van Roosmalen MS, et al. Randomised trial of a decision aid and its timing for women being tested for a BRCA1/2 mutation. Br J Cancer. 2004;90(2):333-42.
Vernon 2011 | Screening promotion | Vernon SW, Bartholomew LK, McQueen A, et al. A randomized controlled trial of a tailored interactive computer-delivered intervention to promote colorectal cancer screening: sometimes more is just the same. Ann Behav Med. 2011;41(3):284-99.
Wahab 2008 | Screening promotion | Wahab S, Menon U, Szalacha L. Motivational interviewing and colorectal cancer screening: a peek from the inside out. Patient Educ Couns. 2008;72(2):210-7.
Weinrich 2008 | Non-clinic setting | Weinrich SP. A decision aid for teaching limitations of prostate cancer screening. JNBNA. 2008;19(1):1-11.
Weinrich 2007 | Non-clinic setting | Weinrich SP, Seger R, Curtsinger T, Pumphrey G, NeSmith EG, Weinrich MC. Impact of pretest on posttest knowledge scores with a Solomon Four research design. Cancer Nurs. 2007;30(5):E16-28.
Wilkinson 2002 | Not cancer screening | Wilkinson CR, Williams M. Strengthening patient-provider relationships. Lippincotts Case Manag. 2002;7(3): 86-99; quiz 100-2.
Williams 2008 | Non-clinic setting | Williams RM, Zincke NL, Turner RO, et al. Prostate cancer screening and shared decision-making preferences among African-American members of the Prince Hall Masons. Psychooncology. 2008;17(10):1006-13.
Williams-Piehota 2008 | Not RCT (secondary observational study from McCormack 2011) | Williams-Piehota PA, McCormack LA, Treiman K, Bann CM. Health information styles among participants in a prostate cancer screening informed decision-making intervention. Health Educ Res. 2008;23(3):440–53.
Wilson 2010 | Not RCT | Wilson CJ, Flight IH, Zajac IT, et al. Protocol for population testing of an Internet-based Personalised Decision Support system for colorectal cancer screening. BMC Med Inform Decis Mak. 2010;10:50.
Wolf 2000 | Decision Action outcome only | Wolf AM, Schorling JB. Does informed consent alter elderly patients' preferences for colorectal cancer screening? Results of a randomized trial. J Gen Intern Med. 2000;15(1):24-30.
Wolf 1996 | Decision Action outcome only | Wolf AM, Nasser JF, Wolf AM, Schorling JB. The impact of informed consent on patient interest in prostate-specific antigen screening. Arch Intern Med. 1996;156(12):1333-6.
Yasunaga 2006 | Non-clinic setting | Yasunaga H, Ide H, Imamura T, Ohe K. Benefit evaluation of mass screening for prostate cancer: willingness-to-pay measurement using contingent valuation. Urology. 2006;68(5):1046-50.