# SEARCH STRATEGIES

## DATABASE: OVID MEDLINE(R)

1. decision making/ or patient participation/ or directive counseling/
2. decision support technique/
3. (decision making or decision-making or decision support or decis$ aid$ or shared decis$ or shared decision making or informed decision making or valu$ or valu$ clarific$).mp.
4. or/1-3 [decision making search terms]
5. limit 4 to (english language and humans and yr=”1995 -Current”)
6. limit 5 to (“all adult (19 plus years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19-24 and 19-44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”)
7. limit 5 to (“newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)”)
8. 5 not 7
9. 6 or 8 [decision making limited to English, humans, 1995-Current, adult]
10. Randomized controlled trials as topic/
11. Randomized controlled trial/
12. Random allocation/
13. Double blind method/
14. Single blind method/
15. Clinical trial, phase iii.pt.
16. Clinical trial, phase iv.pt.
17. Controlled clinical trial.pt.
18. Randomized controlled trial.pt.
19. ((singl$ or doubl$ or treb$ or trip$) adj (blind$3 or mask$3)).mp.
20. Random$ allocat$.mp.
21. (allocat$ adj2 random$).mp.
22. or/10-21 [RCT terms]
23. Meta analysis/
24. Meta analys$.mp.
25. (systematic adj (review or overview)).mp.
26. meta analysis.pt.
27. or/23-26 [SR/MA terms]
28. (neoplasm$ or cancer$).mp. or exp Neoplasms/ [cancer terms]
29. screen$.mp. or screening/ or cancer screen$.mp. or “Early Detection of Cancer”/
30. colonoscopy/ or sigmoidoscopy/ or colonography, computed tomographic/ or barium sulfate/ or Occult Blood/
31. (fobt or fecal occult or colonoscop$ or sigmoidoscop$ or ct colonograph$ or virtual colonoscop$ or barium enema or lower GI series or lower gastrointestinal series or lower gastrointestinal exam$ or FIT or fecal immunochemical test).mp.
32. vaginal smears/ or DNA Probes, HPV/ or Papillomavirus Infections/ or Human Papillomavirus DNA tests/ or CA-125 Antigen/
33. (pap test$ or pap smear$ or hpv or human papillomavirus or TVUS or (transvag$ adj ultraso$) or CA-125).mp.
34. mammography/ or (mammography/ and Magnetic Resonance Imaging/) or (MRI mammogra or mammogra$).tw. or ultrasonography, mammary/
35. prostate-specific antigen/ or (PSA or prostate specific antigen).tw.
36. Tomography, X-Ray Computed/ or Tomography, Emission-Computed, Single-Photon/ or (computed tomography or tomography).tw.
37. or/29-36 (1087048) [screening terms]
38. 9 and 28 and 37
39. 38 and 22 [RCTs]
40. 38 and 27 [SRs/MAs]

## DATABASE: CINAHL

1. (MM “Decision Making”) OR (MM “Decision Making, Clinical”) OR (MM “Decision Making, Patient”)
2. (MM “Cancer Screening”)
3. TX directive counseling OR TX decision support OR TX shared decision OR TX shared OR TX informed OR TX patient participation
4. TX screen* AND TX cancer
5. 1 OR 3
6. 2 OR 4
7. 5 AND 6
8. Narrow by SubjectAge (all adult) AND SubjectMajor (cancer screening)

## DATABASE: PSYCINFO

1. TX Shared OR TX Shared Decision OR TX Decision Support OR TX Informed OR TX Directive Counseling OR TX Decision OR TX Preference OR TX Choice
2. MJ “Cancer Screening”
3. TX PSA OR TX Colonoscopy OR TX Sigmoidoscopy OR TX Colonography OR TX Fecal Occult OR TX FOBT OR TX Pap OR TX cervical OR TX mammography OR TX prostate OR TX tomography
4. 1 AND 2 AND 3
5. Narrow by Methodology (treatment outcome/clinical trial), Narrow by Methodology (quantitative study), Narrow by SubjectAge (adulthood [18 yrs & older])
6. (MJ “Decision Making”) AND (MJ “Cancer Screening”)
7. 5 OR 6