# SUMMARY AND DISCUSSION

The review demonstrates rural healthcare workforce needs, determinants of providers' geographic choices, the lack of intervention studies aimed at US providers, and a multitude of recent provider in training efforts.

We identified a small number of studies quantifying current healthcare provider needs (8 studies). Estimates were for specific regions and specific years, and studies operationalized provider need differently. Hence it is difficult to make concrete or generalizable evidence statements regarding the number of healthcare providers needed. However, all included studies reported current unmet healthcare provider needs that worsen with increasing rurality. There is in particular a healthcare provider shortage for primary care providers, mental health professionals, and general surgeons.

We identified 3 published studies estimating future provider need (KQ1). Studies made predictions for primary care physicians, emergency physicians, and surgeons. We did not identify 2 or more studies reporting on the same provider group. We also did not find studies addressing other provider groups of interest for this review. All studies concluded that the supply is not likely to meet demand.

A large number of studies exploring the determinants of practicing in rural care (KQ2) has been published. Growing up in a rural community was the most consistent factor associated with practice location choice. Education efforts for physicians, such as rural tracks, also seem to increase the likelihood of practicing in a rural community. Positive associations were also shown for family, exposure to rural communities, a primary care and family medicine orientation, osteopathic degree, recreation activities, and rural lifestyle; however, the evidence base is very limited. Although a large number of studies explored potential factors, further studies are needed to determine the relative importance of the predictor variables.

For KQ3, we identified only 5 evaluations that were aimed at practicing providers, J-1 visa waiver, and loan forgiveness program evaluations. A J-1 visa program evaluation reported that 53% of physicians did not complete their obligations but of the respondents who had completed commitments, 84% remained longer than required.^83^ A state-wide evaluation of various recruiting programs reported that 80% of placed providers have remained at their initial placement site upon completion of their obligation.^86^ The loan repayment programs reported on different outcomes. One reported 86% continued medical practice at their sponsoring facility after completing their obligation. One reported that of those recipients whose obligated practice location was rural, 84% were practicing in rural areas and 28% of program completers were practicing in rural areas. One evaluation highlighted that 74% of recipients were already working in or intended to work in an eligible community when they were made aware of the program but the program was important to retention in rural healthcare for 38%.

We did not identify any study specifically aimed at improving retention of fully trained healthcare providers practicing in rural healthcare facilities (KQ4).

We identified a large number of program evaluations focusing on providers in training. However, all were programs aimed at medical students and residents (KQ5). Across individual approaches, studies reported a median success rate for recruitment into rural healthcare of 53%.

## DISCUSSION BY KEY QUESTION

The included studies quantify shortages for rural areas, for specific provider groups (primary care providers, mental health professionals, and general surgeons) and for a defined period of time. The specific estimates of unmet needs underpin the perceived shortage of healthcare providers, in particular for rural areas, as highlighted in numerous publications on the topic.^7,9-11,111-118^ HRSA provides annually updated, online access to all designated Health Professional Shortage Areas (HPSAs) stratified by primary medical care, mental health, and dental health.^119^ The variability in the metrics used to define unmet need illustrate the difficulty of quantifying provider needs and comparing unmet needs across geographic regions and provider disciplines.

Although this review only targeted research describing practicing healthcare providers relevant to the current healthcare system, we identified a large number of studies contributing to key question 2. We identified growing up in a rural community as the most consistent factor associated with practice location choice. This factor has also been identified in earlier datasets^120^ and it appears that this aspect continues to play an important role in determining the choice of location. The recent literature also includes multivariate analyses that were able to confirm the effect without obvious confounders.^72,78^ Despite this association, the evidence suggests that most rural physicians did not grow up in a small town. Among physicians moving to a rural setting, factors such as feeling established in practice with a close connection to patients and location were noted to be of importance. ^65,80^ A second key predictor that emerged in the literature is education efforts such as rural tracks for physicians. These seem to increase the likelihood of practicing in a rural community, and although the choice of selecting a rural track may be in part determined by a personal affinity preceding the choice of school, multivariate analyses showed that the effect cannot be entirely explained by the variable of growing up in a rural community.^72^ However, there is a lack of studies differentiating the relative importance of a personal affinity for rural communities, motivation through rural training, and effects of interventions attracting trained healthcare providers into rural care settings.^61^

For KQ3, we only identified a very small number of studies aimed at the recruitment of healthcare providers for rural communities. This is consistent with a recent Cochrane review on interventions to increase the proportion of health professionals practicing in rural and other underserved areas; the review includes only one study.^121^ The included study reported on an international setting (Taiwan). The Cochrane review concluded that there is currently limited reliable evidence regarding the effects of interventions aimed at addressing the inequitable distribution of health professionals. A 2010 review for the World Health Organization on interventions to increase attraction and retention of health workers in remote areas included 3 studies directed at healthcare providers (rather than providers in training): studies addressed community service for doctors in South Africa, financial incentives in the Niger, and bundled interventions for rural areas in Mali.^27^ Studies reported a 25% proportion of participants placed in rural areas, an increase of 44% in the number of doctors practicing outside the capital city, and the total number of physicians installed in rural areas over a 10-year period (100) but the review cautioned that there is a need for more thorough evaluations to support policy-makers in developing, implementing, and evaluating effective interventions to increase the availability of health workers in underserved areas.

One of the identified evaluations in our systematic review was a J-1 visa waiver program evaluation at state level and it highlighted that programs need to be evaluated carefully. The study reported that half of physicians did not complete their obligation. However, of the respondents who had completed their commitments, over 80% remained longer than required. ^83^ This is mirrored by earlier evaluations of the program; an evaluation for rural Wisconsin concluded that to keep physicians practicing in communities, successful integration into the community is important.^122^ Research on loan forgiveness programs is sparse and the identified evaluations assessed different outcomes and results. Careful evaluation is needed given that one included study highlighted that a large proportion of participants were working in or intended to work in an eligible community when they were made aware of the program. Hence, the program may influence their retention in rural healthcare but was not key to entering rural healthcare.^62^ A critical review of interventions to redress the inequitable distribution of healthcare professionals to rural and remote areas summarized the reviewed literature published to 2008, as many service-lined scholarships, loans, and loan repayment programs have been described, but the effect of these on the rural or remote workforce are not clear.^123^

We did not identify any recent study specifically aimed at improving retention for healthcare providers in rural healthcare facilities (KQ4). This finding is consistent with a recent review on physician recruitment and retention in rural and underserved areas. The review highlighted that several authors have suggested recruitment and retention techniques; however, there is a need for a research agenda that includes valid, reliable, and rigorous analyses regarding formulating and implementing these strategies.^124^ Review articles have frequently pointed to models of telehealth and their expected influence on rural care,^21,36^ but there is a lack of studies providing empirical data of the effects of these innovations. There was a similar lack of evidence to evaluate whether there is a critical duration of rural practice after which providers are more likely to remain in that setting for an extended time or the duration of their career. Furthermore, we did not identify any study assessing the effect of education and continuous professional development on rural healthcare providers. Our review concentrated on specific healthcare provider groups; however, a review of reviews on interventions for supporting nurse retention in rural and remote areas also concluded that more knowledge is needed regarding the effectiveness of specific strategies to address the factors known to contribute to nurse retention,^125^ suggesting that the absence of systematic evaluations is not necessarily provider group-specific. While our review concentrated on the US setting, a 2010 systematic review on the international literature on retention incentives for health workers in rural and remote areas reported that little evidence demonstrated the effectiveness of any specific strategy, with the possible exception of health worker obligation.^126^ The review suggested a framework of 6 components (staffing, infrastructure, remuneration, workplace organization, professional environment, and social, family, and community support) and concluded that retention strategies should be rigorously evaluated.

In the last 10 years a large number of studies have been published that evaluate programs for healthcare providers in training (KQ5). However, the literature is dominated by studies focusing on medical students and residents. Across all approaches, studies reported a median success rate for recruiting healthcare providers to rural care of 53%, meaning that about half the students trained for rural healthcare enter rural settings. The success rate varied across datasets and programs but most estimates ranged between 35 and 65%. This included a study that combined data from 3 identified programs that give preference to students with a rural background and a rural track approach ensuring exposure to rural healthcare; the reported success rate was 63%.^91^ Individual training programs varied widely in format and duration but we did not identify factors that systematically affected success rates. For example, training programs with greater than 6 months' time spent in rural training had a median success rate of 51%, versus 53% for those comprising less than 6 months of rural experience. Our identified data are comparable to the estimate of a prior systematic review with data to 2006 that reported a weighted average 53 to 64%.^127^

While the data contained in the included studies suggest that it is difficult to recruit, retain, and train rural providers, the studies provide little exploration of the specific challenges of rural practice. These challenges are illustrated well in the results of a 2011 survey performed by Chipp et al.^32^ Rural providers were asked, simply, “What are the 3 things you wish someone would have told you about delivering healthcare in rural areas?” Responses relating to challenges of rural healthcare provision frequently touched on challenges in community relationship-building, personal and professional boundaries, and rural lifestyle challenges and self-care practices. One respondent, for example, replied, “Self care is one of the primary things, because of isolation; you have to be a person who knows how to nurture yourself, to replenish yourself.” Although an in-depth discussion of these challenges and difficulties lies outside the scope of this review, these results offer some understanding of the forces shaping the rural provider workforce and the results of the included studies.

## LIMITATIONS

Workforce supply and demand is part of a complex and dynamic system. While our review targeted only recent research, that is within the last 10 years, the effects of newer developments such as the Affordable Care Act will add new components.^128^ Our systematic review captures research published to February 2015 but publications continue to address this complex topic.^129,130^

We restricted the review to a specific range of healthcare disciplines, chosen by consensus as those most frequently appearing in the literature pertinent to Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals. Additional providers, whose role in providing rural care may be relevant, fell outside the scope of the study. HRSA provides information on health workforce projections for various other healthcare providers such as psychologists and pharmacists.^131^

Our review focused on specific empirical evidence, for example provider demand estimates, and program evaluations for healthcare practitioners had to report on recruitment or retention measures to be eligible. This left out studies assessing supply, rather than demand,^132,133^ or evaluations assessing provider satisfaction with programs.^134-136^

Finally, as shown in the evidence tables throughout the report, “rural” was operationalized differently across identified studies which introduced heterogeneity across studies.

## RESEARCH GAPS/FUTURE RESEARCH

Supply information is now widely available. However, few studies exist that have quantified provider needs for rural areas. HRSA provides a model for estimating provider demand that can be used for estimates. Predictive models are very complex and need to be continuously updated due to developments such as the Affordable Care Act. Although the shortage of healthcare providers is often cited, specific estimates are needed, in particular for healthcare providers other than physicians. Furthermore, there is a need to identify and assess the skills and competencies needed by current and future rural healthcare providers, in order to optimize the impact of these providers, to predict the supply and demand according to geographic region, to shape new models of care, and to effectively utilize technology to ameliorate issues physician shortage and patient access. The impact of federal and state policies on supply and demand warrants investigation. In particular, research considering the context above and focusing on VA-specific care in rural settings is needed.

Although we have identified many studies addressing providers' geographic choices for practice, few were designed to determine the relative importance of contributing factors. For physicians in particular, studies should focus on the context of rural upbringing, academic preparation, and competitive medical school admissions processes to understand individual decisions of where providers choose to practice. In addition, there is a need for further, multivariate analyses, simultaneously exploring the effects of personal background, training, time spent in rural placements, and interventions aimed to recruit healthcare provider groups for rural care.

We identified only very few intervention evaluations that targeted providers, rather than students and residents. In particular, empirical evidence of strategies to improve provider retention in rural areas is missing. There is a lack of intervention studies evaluating organizational interventions (eg, estimating the effect of implemented continuous education, clinical support, and inter-professional collaboration). We also did not did not identify evaluations that reported on the current effect of a federal program, the National Health Service Corps. Earlier evaluations were positive^137,138^ but effect estimates should be intermittently updated to assess effects of the American Recovery and Reinvestment Act and the Patient Protection and Affordable Care Act.^19^ In recent years, additional approaches to recruiting and retaining US healthcare providers have been suggested that should be evaluated in future research studies.^139-142^ Data is currently lacking on the effects of improved access to Continuing Medical Education, availability of e-consults with specialists, expanded consult networks, and other interventions aimed at improving ease of practice in rural areas.

Studies of training interventions for students and residents varied widely in duration, intensity, balance of acute care to rural or primary care exposure, geographic regions, program elements, and other factors making impacts difficult to compare across studies. Analyses are needed that parse out the specific aspects of the training experience that influenced success. To date it is, for example, unknown whether the rural-specific skills training is crucial, or if simply spending time in the rural setting is sufficient. There is a lack of studies evaluating the comparative effectiveness of different training programs. Moreover, effects of training programs for healthcare providers other than medical students and residents are needed, at least to demonstrate that effects are comparable to medical school training efforts.

## CONCLUSIONS

All included studies reported current unmet healthcare provider needs that worsen with increasing rurality. The small number of studies estimating future need also predicted unmet provider needs for rural healthcare.

Growing up in a rural community is the most consistent factor associated with practice location. Education efforts for physicians, such as rural tracks, also seem to increase the likelihood of practicing in a rural community. More research on the relative importance of factors is needed.

More research is needed to evaluate existing healthcare provider recruitment interventions for rural healthcare.

There is a lack of evidence regarding interventions to support healthcare provider retention in rural healthcare.

Current evaluations of rural training programs for medical students and residents suggest a median success rate of 53%.