# RESULTS

The identified research was summarized in a narrative synthesis.

## LITERATURE FLOW

The literature review identified 5,756 potentially relevant citations. In total, 446 citations were obtained as full text. Of these, 59 publications met inclusion criteria, contributing to one or more key question. The flow diagram shows the number of identified studies through the literature search, studies meeting inclusion criteria, and the number of excluded studies with the reason for exclusion.

The publications not meeting inclusion criteria are listed in Appendix 2, ordered by reason for exclusion.

Figure 1 Literature Flow Chart

* Some studies address more than one key question.

## KEY QUESTION 1 What are the current versus projected healthcare provider needs by numbers and disciplines in the next 20 years in rural areas?

The following evidence table (Table 1) summarizes all identified studies contributing to this key question with associated predictions of provider needs and study conclusions. Studies estimating current need are listed first, followed by 3 predictive studies.

Table 1 Evidence Table – KQ1 (Provider Need)

ID | Region Provider | Data Timeframe | Analysis | Definition of need Definition of rural | Results | Conclusion
Current Need
Branch, 2014^47^ | Alaska Allied health and ancillary services, counselors and behavioral therapists, nurses, physicians, and dentists | 608 respondents (67%) out of 906 surveyed employers Timeframe: 2012 | For each occupation, sample (unweighted) and population (weighted) estimates were calculated | Need: Estimated rural vacancy rates Rural: Labor market regions in Alaska, as defined by the Department of Labor: Anchorage (urban), Fairbanks (urban), Juneau (rural), Gulf Coast – Rural South Central (rural), North (rural), Rural Interior (rural), Rural Southeast (rural), and Southwest (rural). | Rural areas suffer from extreme shortages in traditional primary care occupations. Estimated rural vacancy rates were: family physicians (21%), family nurse practitioners (17%), physician assistants (19%), women's healthcare nurse practitioners (44%), psychiatric nurse practitioners (16%); psychiatrists (15%), emergency physicians (21%), general practitioners and family physicians (21%), pediatricians (16%). Estimated vacancy rates for general practitioners and family physicians in North (26%), Southwest (25%), Gulf Coast Rural Southcentral (18%), and Gulf Coast Rural Southeast (16%); all are rural regions | Alaska must address challenges inherent in developing and sustaining a high-quality and stable health workforce if it wants to maintain access to healthcare services and care for its residents far into the future. This can be accomplished by: 1) making long-term investments to prepare students in middle and high school for health-focused post-secondary programs, 2) developing and sustaining post-secondary programs to keep Alaskans here to study and practice, 3) examining laws and restrictions related to barrier crimes, alerting Alaska's youth to be aware of the career consequences of their actions, and 4) continuing to invest in state-based loan repayment and incentive programs for health providers to come to Alaska's rural communities to practice.
Ghosh, 2011^51^ | US Psychiatric mental health-advanced practice registered nurses (PMH-APRNs) | American Nurses Credentialing Center, listing of the employment ZIP codes of certified PMH-APRNs (N = 10,452) Timeframe: 2007 | Geographical analysis of the distribution of PMH-APRNs | Need: Lower than expected number of providers, population-weighted Rural: Counties divided into 6 urban-rural categories on the basis of the 2006 National Center for Health Statistics (NCHS) classification scheme | A significant number of counties with low or very low concentration of PMH-APRNs were rural counties (N = 150). Among counties with very high cluster types (high concentration of PMJ-APRNs), a higher numbers of counties were from large central metropolitan (N = 35) and large fringe metropolitan areas (N = 80), emphasizing an uneven distribution of PMH-APRNs among urban and rural counties | The interdisciplinary approach, including both mapping and statistical analyses, identified shortage areas and provided the groundwork for directing future education, clinical practice, and public policy initiatives.
Hendryx, 2008^54^ | Appalachian region in 13 states Mental health professionals: psychiatrists, clinical psychologists, clinical social workers, psychiatric nurse specialists, and marriage and family therapists | 2005 Area Resource File merged with data from Bureau of Health Professions, US DHHS, HRSA. (N = 618 counties) Timeframe: 2005 | Descriptive and bivariate analyses and a series of maximum likelihood logistic regression analyses | Need: HRSA-designated mental health professional shortage area Rural: Appalachian counties that were designated as nonmetropolitan according to US Department of Agriculture urban influence codes were selected, and metropolitan counties (code 1 or 2) were excluded. | Of the 268 non-metropolitan Appalachian counties, 69.8% were designated as mental health professional shortage areas, compared to 57.7% of non-metropolitan, non-Appalachian counties within the same states (p<.002) | Appalachian location is associated with mental health professional shortages, but this effect is driven by underlying social differences, in particular by lower education. This method of identifying Appalachia for comparative purposes may be applied to many other health services research questions and to other defined geographic regions.
Maizel, 2009^48^ | Maryland Surgeons | Maryland Board of Physicians licensing files for 2006-2007 and interviews with medical directors of 52 acute care hospitals Timeframe: 2006 to 2007 | Clinical FTE per 100,000 residents | Need: Benchmark 6.4 practicing general surgeons per 100,000 residents Rural: western (4 counties), southern (3 counties), and eastern (9 counties) regions. Metropolitan: central (5 counties and Baltimore). Suburban: capital region (2 counties) | The number of surgeons providing care to patients per 100,000 residents was below reported requirements in general surgery (western: 6.5, southern: 3.28, eastern: 6.26; vs central: 6.15, capital: 4.02). Surgeons in rural areas spent 86.3% of their time on patient care, as compared to 70.3% of surgeons in urban, suburban, or teaching settings | Critical shortages of qualified surgeons currently exist in many regions of Maryland, especially in rural regions. Administrative, teaching, and research activities significantly reduce the amount of time surgeons are able to devote to patient care, particularly in academic and suburban settings. Fewer surgeons are available to care for patients in Maryland, and they are significantly older than assumed in manpower databases. Access to surgical care in Maryland will be jeopardized if these issues are not considered in future healthcare workforce discussions.
Rayburn, 2012^52^ | US Obstetricians and gynecologists (ob-gyn) fellows and jr. fellows | 2010 US County Census File for women of reproductive age and the 2010 ACOG membership roster Timeframe: 2010 | Ob-gyn distribution was divided into 2 county groups and state data were categorized as density of ob-gyns by state and district | Need: Absence of ob-gyn; benchmark: 1 per 10,146 general population or 2.5 per 10,000 women Rural: US Office of Management and Budget's statistical area definitions | Density of ob-gyns declined from metropolitan to micropolitan and to rural counties. The mean population in counties with no ob-gyns was much lower than in counties with 1 or more ob-gyns | An uneven distribution of ACOG Fellows and Junior Fellows in practice exists throughout the United States and may worsen if resident graduates continue to cluster in metropolitan areas. Meeting the needs of women in underserved areas requires creative innovations in enhancing a more uniform geographic distribution of providers.
Rosenblatt, 2010^1^ | US Medical school graduates 1988-1997 | 2005 AMA and AOA Masterfile Timeframe: 2005 | Cross-sectional analysis | Need: Relative shortage of rural compared to urban physicians Rural: ZIP code-derived RUCA code; urban, large rural, small rural, and isolated small rural categories | Relative shortage of physicians in rural areas remains: urban areas have 210 physicians per 100,000 people, isolated small rural areas have 52. Generalists represent 35.9% of all physicians in the US but account for almost half of all physicians in large rural areas, indicating rural areas rely on physicians for their healthcare. Specialty supply diminishes as areas become smaller and more remote | The precipitous decline in the number of US medical graduates choosing family medicine residencies, and the decline in the number of graduates from these residencies despite the importation of large numbers of international medical graduates, has led to increasing shortages of rural physicians and threatened the integrity of the rural healthcare system. Future projections of population growth suggest that the shortages will worsen unless the private and public sectors work together to change the dynamics that affect the choice of medical career and practice location.
Stewart, 2013^49^ | Texas General surgeons | Texas Medical Board, the US Census Bureau/Texas State Library and Archives Commission, and the Texas Department of State Health Services Timeframe: 2002 to 2012 | Unadjusted data and data normalized per 100,000 population for 2002 and 2012 | Need: Benchmark standard: 7 general surgeons per 100,000 population Rural: N/A | From 2002-2012, the Texas population increased 21%, actively practicing physicians 44%,and general surgeons increased 4%. The number of general surgeons per 100,000 population decreased 14% (P<.01). In 2012, 329 additional general surgeons were needed by benchmark standards. When analyzed by county, 449 additional general surgeons were needed in the individual counties. Effects were greater in nonmetropolitan areas (per capita general surgeons decreased by 21%) | The absolute increase in Texas general surgeons over the past decade has not kept pace with an increase in the Texas population. The general surgery workforce deficit based on the Texas state population underestimates the local workforce shortage, particularly in the nonmetropolitan areas of Texas.
Thomas, 2009^50^ | US, counties Psychiatrists, psychologists, advanced practice psychiatric nurses, social workers, licensed professional counselors, marriage and family therapists | Supply data compiled from professional associations, state licensure boards, and national certification boards Timeframe: 2006 | County-level need measured by estimating prevalence of serious mental illness, combining separate estimates of provider time needed derived from National Comorbidity Survey Replication, US Census, and Medical Panel Expenditure Survey data; shortage measured for prescribers, nonprescribers, and a combination; ordinary least-squares regression identified county characteristics associated with shortage | Need: Shortage = % unmet need for mental health visits within county Rural: 9-point rural-urban continuum code | 77% of counties had a severe shortage of mental health prescribers or non-prescribers, with over half their need unmet. 96% had at least some unmet need for prescribers. Rurality and per capita income were the best predictors of unmet need. A 1-point increase in rurality on the Rural-Urban Continuum Code corresponded to an increase in unmet need of 3.3% points | These findings identified widespread prescriber shortage and poor distribution of nonprescribers. A caveat is that these estimates of need were extrapolated from current provider treatment patterns rather than from a normative standard of how much care should be provided and by whom. Better data would improve these estimates, but future work needs to move beyond simply describing shortages to resolving them.
Predicted Need
Camargo, 2008^56^ | US Emergency medicine physicians | 2005 NEDI-USA Timeframe: 2005 to 2040 | 3 models (best-case, worst-case, intermediate scenario), Emergency Medicine Workforce Calculator (http://www.emnet-usa.org/nedi/workforce.html) | Need: Demand estimate accounted for attrition, demand = # ED visits in 2005 per 3,548 visits, assuming 1 emergency physician 24/7 coverage = 5.35 FTE Rural: Located in a county not in a metropolitan statistical area | A total of 40,030 emergency physicians were needed to staff all EDs (55% of demand met); 6,450 (16%) were needed in rural EDs and 33,580 (84%) in non-rural EDs | Supply of EM residency-trained, board-certified emergency physicians is not likely to meet demand in the near future; alternative emergency physicians staffing arrangements merit further consideration.
Williams, 2011^53^ | US Surgeons (ob-gyn and general surgeons) | AHA's Fast Facts survey in 2008 Timeframe: 2011 to 2030 | Population analysis algorithm; Census figure of 309 million in 2010 as a baseline for US population, 3,012 urban hospitals, and 1,998 rural hospitals | Need: Ratio: 7.5 general surgeons per 100,000 Rural: RUCA classification | From 2011-2030, rural hospitals will have to recruit an average of 3.4 ob-gyns, 1.6 orthopedics, and 2.0 general surgeons for a total of 7 FTEs. Urban hospitals have to recruit 10 ob-gyns, 6 general surgeons, 5 ear, nose, throat surgeons, 2.5 urologists,1 neurosurgeon, and 1 thoracic surgeon | Rural hospitals will be in competition with urban hospitals for hiring from a limited pool of surgeons. As urban hospitals have a socioeconomic advantage in hiring, surgical care in rural areas may be at risk. It is imperative that each rural hospital analyze local future healthcare needs and devise strategies that will enhance hiring and retention to optimize access to surgical care.
Wilson, 2011^55^ | Kentucky Primary care physicians | Kentucky Board of Medical Licensure, Area Resource File, US Census Small Area Health Insurance Estimates, Kentucky State Data Center, and National Resident Matching Program Timeframe: 2005 to 2020 | HRSA model applied to Kentucky's 120 counties | Need: Physician Supply Model and Physician Requirements Model (HRSA) used to estimate need (preventive, acute, and chronic care) and demand (all healthcare services wanted) Rural: US Department of Agriculture's RUCC | 1,527 additional primary care physicians are needed to meet projected needs and 1,888 additional primary care physicians are required to meet projected demands by 2020 in Kentucky. 43% of the population resides in rural communities | No single policy can solve the shortage of primary care physicians; therefore, multiple approaches must be used at the local, state, and national levels; a new system of care, patient centering, to reform the healthcare system is also suggested.

Note: ACOG = American Congress of Obstetricians and Gynecologists, AHA = American Hospital Association, AMA = American Medical Association, AOA = American Osteopathic Association, 95% CI = cconfidence interval, DHHS = Department of Health and Human Services, FTE = full-time equivalent, HRSA = Health Resources and Services Administration, NCHS = National Center for Health Statistics, NEDI = National Emergency Department Inventories, PA = physician assistant, PMH-APRNs = psychiatric mental health-advanced practice registered nurses, RUCA = Rural-Urban Commuting Area, RUCC = Rural-Urban Continuum Codes

### Current Healthcare Provider Need

We systematically identified published studies investigating current healthcare provider demand and reporting specific estimates for the provider groups of interest. Identified studies used employer surveys,^47^ state or national provider-specific files,^48-51^ specialty-specific national provider membership rosters,^50,52^ and existing data sets^1,52^ to estimate current rural healthcare provider needs. Most studies reported on physicians^1,47-50,52^ with one broadening to include allied health providers, advanced practice nurses, physician assistants or dentists,^47^ and 2 reported on mental health professionals.^50,51^ Provider groups consisted of family physicians and general practitioners,^1,47^ psychiatrists,^47,50^ psychiatric mental health advanced practice registered nurses (PMH-APRNs),^51^ pediatricians,^47^ emergency physicians,^47^ obstetrics and gynecology or women's health providers,^47,52^ and general surgeons^48,49^

When reporting provider need, results were presented as national unweighted or population-weighted estimates,^1,51,52^ state-specific need,^47-49^ county-level need^50^ or reported vacancy rates.^47^ Rurality was designated according to labor market regions,^47^ state designation,^48^ the US Office of Management and Budget's statistical area definition,^52^ the US Department of Agriculture Rural-Urban Continuum Code (RUCC),^53,54^ the Rural-Urban Commuting Area (RUCA) codes,^1,50^ or were based on the National Center for Health Statistics (NCHS).^51^ One study did not define rural.^49^

### Predicted Future Healthcare Provider Need

We systematically identified published studies predicting future healthcare provider demand. Three identified studies used either state-specific physician provider files,^55^ or existing national data sets.^53,56^ Provider groups consisted of primary care physicians,^55^ surgeons,^53^ or emergency medicine physicians.^56^ Predictive models reported tiered scenarios (best-case, worse-case, intermediate scenario),^56^ population analysis algorithms,^53^ or previously described models (ie, Health Resources and Services Administration [HRSA] model).^55^ Metrics for assessing need were not standardized across studies; 2 studies reported national need in comparison to expected provider-to-population-based ratio^53,56^ and one study reported county-based need for a state.^55^

Predictive time frames were 2005 to 2040^56^, 2011 to 2030,^53^ and 2005 to 2020.^55^ Rurality was designated according to location outside of a county metropolitan statistical area,^56^ RUCC,^53,54^ or RUCA classification.^55^

### Summary of Findings and Quality of Evidence for Key Question 1

The summary of findings table summarizes the results for current and future provider demand across the included studies.

Table 2 Summary of Findings – KQ1

Provider need | # studies | Results for rural health
Current demand
Primary care providers | 2 | Isolated rural areas have one-quarter the ratio of physicians per capita^1^ Rural areas in Alaska continue to suffer from extreme shortages in traditional primary care occupations^47^
Psychiatrists and mental health professionals | 2 | 77% of counties in US had severe shortage of psychiatrists.^50^ Rural areas of Appalachia more likely to be designated mental health professional shortage areas ^54^
General surgeons | 2 | Critical shortage in rural areas of Maryland ^48^ Per capita general surgeons in Texas decrease 21% from 2002-2012; 449 additional general surgeons required in individual counties^49^
Ob-Gyn in rural areas | 1 | Rural areas currently underserved for ob-gyn based on national data^52^
PMH-APRNs | 1 | Analysis of lower than expected numbers of PMH-APRNs highlights the uneven distribution among urban and rural counties^51^
Future demand
Primary care physicians | 1 | Approximately 1700 additional primary care physicians needed in Kentucky by 2020 ^55^
Emergency physicians | 1 | 16% of emergency physicians need to be recruited to rural locations; demand is unlikely to be met based on national data^56^
Surgeons (ob-gyn and general surgeons) | 1 | Rural hospitals need to hire 7 physicians (on average) by 2030 to compete with urban hospitals, based on national data^53^

Although we identified 2 studies reporting on primary care provider needs, mental health professionals, and general surgeons, the included studies quantified healthcare provider needs for specific regions and specific years, and operationalized provider need differently. Hence it is difficult to make concrete evidence statements for the number of healthcare providers needed across the studies. However, all included studies reported current unmet healthcare provider needs that worsen with increasing rurality. Based on the existing evidence base, our confidence is high that there is a shortage for primary care providers, mental health professionals, and general surgeons.

We only identified one study each reporting on obstetrics and gynecology physicians and psychiatric mental health advanced practice registered nurses. Both studies did not provide an estimate of how many providers are needed to meet demand but pointed to the absence of providers in rural areas and reported a decreasing density from metropolitan to rural counties.

We identified 3 studies estimating future provider demand. All included studies predicted unmet provider needs that worsen with increasing rurality. However, the identified studies reported on individual healthcare provider groups: primary care physicians, emergency physicians, and obstetrics/gynecology and general surgeons. We did not identify more than one study reporting on the same provider group. The studies reported specific estimates of how many additional physicians are needed, but it is difficult to judge our confidence in the estimates in the absence of replication, in particular given the complexity of future demand estimates. However, all 3 studies concluded that the supply is not likely to meet demand, regardless of the individual provider group studied.

We did not identify any published estimates from VA datasets.

## KEY QUESTION 2 What factors influence healthcare providers' geographic choices for practice?

We systematically identified studies investigating factors that may influence providers' geographic choices for practice with regard to rural healthcare. A large number of studies contributed to this key question. Some identified studies used provider surveys and self-reported reasons for selecting rural healthcare; other studies were qualitative analyses of in-depth interviews with a small group of healthcare providers; some studies used existing datasets to identify predictors of practicing in rural healthcare.

The large majority (19) of identified studies evaluated physicians, 3 studies explored the choices for practice in physician assistants, and one included a range of healthcare providers eligible for a loan repayment program. Some studies differentiated allopathic and osteopathic degrees, and several limited to primary care physicians, emergency department physicians, and general surgeons. All studies addressed reasons for choosing to practice in rural areas in the last 10 years, that is from 2005 onwards. Of those studies that limited their study to a particular year, 4 used a 2005 dataset,^57-60^ 2 a 2007 dataset,^61,62^ and 2 a 2009 dataset.^63,64^ The other studies used other years or a range of years with data for practicing in rural care. The number of participants ranged from 8^65^ to datasets with information on over 175,000^57^ healthcare providers.

The majority of studies reported on practicing in rural care. Others investigated specific outcomes such as practicing in a rural satellite clinic, or practicing in a small town. Although a number of studies used an urban-rural continuum to differentiate practice locations, outcomes were analyzed dichotomously (eg, rural versus not). Definitions of “rural” referred to federal taxonomies such as RUCA codes, US Department of Agriculture county-based Urban Influence Codes, RUCC, and the Rural Office of Management and Budget designation, and state definitions, including the Illinois Department of Public Health designations of rural areas and the California Office of Statewide Planning and Development (OSHPD) definition of Rural Medical Service Study Areas. One study used the Rural-Urban Density Typology (RUDT) based on population density and 2 studies referred to a population of less than 50,000 people. Other studies used local definitions (eg, the Hawaiian island O'ahu was considered urban, all other areas rural) or did not define “rural.”

The evidence table summarizes all identified studies contributing to this key question. We differentiated the dependent variables (ie, the predictors or named choices for choosing rural care) by demographic background factors, variables associated with the training of the provider, financial aspects and incentives, aspects of the rural area, and other relevant results. The evidence table also shows the authors' conclusions drawn from the study.

Table 3 Evidence Table – KQ2 (Provider Choice Assessments)

ID | Participants | N, study design, outcome | Results – demographic background | Results – training | Results – financial aspects | Results – rural care characteristics | Other results | Authors' conclusions
Chen, 2010^57^ | Clinically active MDs, DOs, and international medical graduates (IMGs) who graduated from medical school between 1987-1997 Practicing physicians | N = 175,649 Analytic study Rural: RUCA and county designations Outcome: Practicing in rural location in 2005 | In 2005, 18% of DOs, 11% of MDs, and 13% of IMGs are practicing in a rural location. 31% of rural physicians were women (37% of MDs and 31% of DOs female). An increasing proportion of female physicians entered rural practice over the study period (7.8% to 9.8% female MDs, 12.2% to 17.7% female DOs). Overall, 94% of physicians were MDs and 6% DOs, but 18% of DOs and 11% of MDs practice in a rural care | Of the 1.4% MDs trained in rural residency, 36% were in rural practice. Of the 3.6% DOs trained in a rural residency, 50% were in rural practice. Rural residents were 3× more likely to practice in rural areas (RR 3.4, P<.001). Rural residents account for 5% of MDs and 10% of DOs in rural areas. 60% of rural family medicine residents were in rural practice and were 3× more likely to practice in rural care (RR 2.8, P<.001). Only 9% of rural family providers trained in a rural residency | N/A | N/A | N/A | The proportion and number of physicians entering rural practice has remained stable compared with earlier analyses. However, recent trends such as declining primary care interest are not yet reflected in these data and may portend worsening shortages of rural physicians.
DHHS, 2006^66^ | US 18 specialties | N = N/A Analytic study Rural: N/A Outcome: Working in rural area | Female physicians are less likely to work in rural areas | N/A | N/A | N/A | N/A | The growth and aging of the US population will cause a surge in demand for physician services; if current healthcare utilization and delivery patterns continue, the overall supply of physicians should be sufficient to meet the expected demand through the next 10 years.
Duffrin, 2014^67^ | Current members of the North Carolina Medical Board who are listed as primary care physicians Primary care physicians practicing in family medicine, internal medicine, ob-gyn, general practice, and pediatrics | N = 975 Survey Rural: County of <50,000 people Outcome: Practicing in rural area and practicing physicians in 2012 | Population of hometown =<11,000 was associated with working in non-metro area (p = .007, 1st subgroup) | N/A | Pay as a factor in choosing a work site, financial support from a hospital, and medical school loan repayment were correlated with rural practice (effect size not reported) | N/A | | Federal and state incentives should continue; having been raised in an area of 11,000 or less was highly predictive of future rural medical practice and could be used in the recruitment of physicians and residents to increase the ultimate yield for rural areas.
Fordyce, 2012^58^ | MDs and DOs from 2005 AMA and AOA Masterfiles Practicing physicians, non-federally employed, aged 70 years or younger | N = 231,660 Analytic study Rural: RUCA classification (urban, large rural, small rural, or isolated small rural) Outcome: Practicing in rural areas in 2005 | IMGs comprised 22.2% of total clinically active workforce, but contributed 19.3% to the rural PCP workforce, some geographic variation. IMG PCPs were more likely than other PCPs to practice in rural persistent poverty locations (12.4% vs 9.1%). The proportion of rural PCP workforce represented by IMGs decreased with increasing rurality. | DOs comprised 4.9% of clinically active workforce but contributed 10.4% to rural PCP workforce, some geographic variation. DO PCPs were more likely than allopathic PCPs to practice in rural places (20.5% vs 14.9%). Proportion of rural PCP workforce represented by DOs increased with increasing rurality | N/A | N/A | N/A | DO and IMG PCPs constitute a vital portion of the rural healthcare workforce; their ongoing participation is necessary in addressing existing rural PCP shortages and handling the influx of newly insured residents as the ACA comes into effect.
Glasser, 2010^68^ | Recently located rural physicians and graduates of a rural medical education program in rural Illinois | Interviewees (N = 20), graduates (N = 107) Other design Rural: Illinois Department of Public Health designations of rural areas Outcome: Practicing in rural county | Major reason for practicing in a rural location was family ties to the community (50%). | N/A | 2nd major reason for practicing in a rural location was a loan or scholarship obligation (30%). | Top attributes potentially affecting retention were hard work/long hours (25%) and patients not paying enough or being uninsured (20%). Most positive factors were patients' appreciation (45%), lifestyle/work-life balance (20%), and meeting individual and community needs (20%) | N/A | Keys to success in rural physician retention seem to include identifying and recruiting medical students of rural origin and focusing on a healthy practice environment; policy makers need to work with local government, schools and employers to offer programs to identify local youth for induction in rural healthcare.
Hancock, 2009^69^ | PCPs practicing in rural northeastern California and northwestern Nevada PCPs | N = 22 interviewees Other design California OSHPD Rural Medical Service Study Areas (density <250 persons per square mile, no census-defined place >50,000) Outcome: practicing in rural areas in northeastern California and northwestern Nevada (2006-2007) | Rural exposure via upbringing and recreation, and a history of strong community or geographic ties facilitates future rural practice. | Rural exposure via education facilitates future rural practice | N/A | N/A | Exposure facilitates through desires for familiarity, sense of place, community involvement, and self-actualization | Results support a focus on recruitment of rural-raised and community-oriented applicants to medical school, residency, and rural practice. Local mentorship and “place-specific education” can support the integration of new rural physicians by promoting self-actualization, community integration, sense of place, and resilience.
Helland, 2010^70^ | Emergency medicine residents who graduated from 2006 to 2008 and practice in rural EDs, and a random sample practicing in urban EDs. Emergency medicine physicians | N = 197 Survey Rural: Based on US Department of Agriculture county-based Urban Influence Codes Outcome: Practicing in rural EDs (graduated 2006-2008) | Rural practice location was associated with 18 childhood years in a rural area (42% rural vs 24% urban), but was not associated with 1 to 17 years or 0 years of childhood spent in a rural area. Important factors reported for choosing practice location included family/spouse (81% rural vs 72% urban) and previous time spent in similar area (61% rural vs 53% urban) | Emergency medicine board certification was associated with rural practice. Practice location was not significantly correlated with rural residency rotation. No difference was observed between rural vs urban providers reporting residency rotation as an important for choosing practice location. 25% of urban physicians considered practicing in a rural area immediately after graduation | Cost of living, salary signing bonus, and loan repayment were not rated as important. There was a significant difference in ratings between urban and rural providers for the importance of loan repayment | Important factors for choosing practice location included lifestyle (78%), but not access to CME, service to the underserved, autonomy/scope of practice, or access to specialists. 43% vs 56% of rural vs urban providers rated ED volume as very important; 53% vs 68% access to amenities/recreation | Rural and urban physicians reported similar plans for duration of practicing in their type of area for greater than 10 years (57% vs 60%) and for less than 2 years (6% vs 5%) | Promising strategies for recruiting new residency graduates to rural EDs are selection of individuals with a rural upbringing and higher salaries; increasing the availability of rural rotations during emergency medicine residency also may help to motivate and prepare some new graduates to practice in rural EDs.
Heneghan, 2005^71^ | General surgeons practicing in the US General surgeons | N = 421 Survey Rural: OMB designation, Goldsmith modification Outcome: Difference in ratings between rural and urban surgeons | N/A | N/A | Reporting income as having a high impact on practice location was lower among rural surgeons (19.8% rural vs 36.1% urban, p = .0002) | The impact of potential for professional growth, availability of hospital facilities, quality of surgical community, and quality of medical community (all factors p<.001) on location preference were rated differently between rural and urban groups. Quality of life was not rated as an important factor | N/A | Although rural and urban surgeons do not differ in age or the importance of lifestyle in deciding career location, different factors do impact their choice of location; practice pattern and educational needs varied markedly between rural and urban general surgeons.
Henry, 2007^65^ | Physicians assistants (PAs) in Texas who work autonomously in a rural health clinic, sole PCP in community for >24 months. Town with <5,000 persons, no other primary care within 25 miles. PAs | N = 8 Survey Rural: Town with < 5,000 people Outcome: Important factor influencing to work in a rural satellite clinic in 2005 | Majority (7/8) did not grow up in small town. Confidence to practice without physician was an important factor influencing to work in a rural clinic | N/A | N/A | Desire for small-town life, importance of knowing patients on a personal level, and spouse value of small-town life influenced work in rural clinic | N/A | In order to increase retention rates, PAs committed to autonomous, rural primary care would benefit from additional training, particularly in emergency medicine, the benefits of community involvement, and adaptation to the local culture.
Hughes, 2005^72^ | Family practice graduates from UCSF-Fresno residency from 1970-2000 with US high school addresses Family practice graduates | N = 178 Analytic study Rural: RUCA 7-9 (small towns), 10 (rural) Outcome: Practicing in rural areas | Rural high school location was significantly associated with practice in rural areas (OR 5.7, CI 2.0 to 16.4), controlling for high school in high minority areas, medically underserved areas, rural training track, age, gender, minority, and Hispanic ethnicity. 32% of graduates practicing in a rural location graduated from a rural high school, compared with 11% in a non-rural practice | Rural training during residency was associated with rural practice (OR 2.7, CI 1.2 to 6.4) when controlling for rural high school, minority % population of high school, high school in medically underserved area, age, gender, minority, Hispanic | N/A | N/A | N/A | Census data from the residency graduate's high school predicted rural practice and practice in a proportionally high-minority community, but not in a federally designated medically underserved area.
Jarman, 2009^73^ | Surgery residents graduates of all 4 Wisconsin programs from 1994-2008 General surgeons and subspecialty surgeons who completed general surgery residency | N = 45 Survey Rural: Rural = population of <50,000 people Outcome: General surgery practice in rural location 1994-2008 | Factors associated with rural vs urban practice included attending a nonurban high school (p = .001) or college (p = .001), location spouse/partner grew up (p = .022), and having a child before/during medical school (p = .043). Graduates in an urban setting were more likely to have a parent with a medical occupation (p = .03). Practice location was not associated with sex, birthplace (US-only, rural vs non-rural), parental occupation, having a parent who grew up on a farm, participation in high school or college sports, participation in high school academic club, playing a musical instrument, listening to all types of music, being married, being married during college or before, or having children | Factors associated with rural practice included completing a rural clerkship (p = .001) and having chosen a surgical residency program committed to rural training (p = .046). Factors negatively associated with rural practice included completion of a fellowship (p<.001) and teaching surgical residents (p<.001). Practice location was not associated with clinical research during residency or bench research during residency | N/A | Factors positively associated with rural practice included interest in hunting birds (p = .010) or large game (p = .001). Graduates in rural practice more often cited “broad scope of practice” as an important reason. Practice location was not associated with current hobbies, fishing, hunting small game, happiness with location, spouse's happiness with location, or satisfaction with scope of practice | | General surgery residency graduates and their spouses who choose rural practices are more likely than those selecting urban practices to have rural backgrounds and interests; completing a rural clerkship during medical school and choosing a residency program committed to rural general surgery preparation are strongly correlated with rural practice.
Kimball, 2007^74^ | Female physicians practicing in rural Wisconsin Physicians | N = 10 Other design Rural: Wisconsin communities <16,000 people Outcome: Motivation to enter rural practice, reasons for choosing practice location | 70% had a rural background. 60% stated they were always interested in rural practice. Reasons for choosing location included proximity to family (60%) or personal connection to area (60%). 60% stated that family obligations did not influence decision to practice in current community. Family obligations (10%) and spouse's job location (30%) influenced some participants | 20% stated that their medical school had encouraged rural practice, 40% stated that it was discouraged, 40% stated that no specific practice location had been emphasized | N/A | Reasons for choosing practice included liking the community (60%), good access to specialist backup (20%), and full scope of practice (10%) | N/A | The participants provided insight into motivating woman to enter rural practice, finding a balance between the challenges and benefits of rural medicine, and promoting the future of rural healthcare.
Mason, 2012^63^ | 1990-1999 UMC graduates practicing in Mississippi (MS) from 2004 MS Board of Medical Licensure Physicians | N = 927 Analytic study Rural: N/A Outcome: Practicing in small town in 2009 | Factors not associated: attended high school in MS, attending college in MS, internship in MS, began practice in MS, moved practice to MS, age, sex, race, or marital status | UMC graduates were not more likely to practice in rural areas in MS than physicians who graduated elsewhere. PCPs were 2.4 times (P<.001) more likely to practice in small town areas than specialists (controlling for all other factors) | Salary or student loan debt were not predictors of practicing in small towns (multivariate analysis). | N/A | N/A | Health educators and policy makers should consider broadening the enrollment policies and greater emphasis should be placed on recruiting physicians.
Pepper, 2010^75^ | Physicians in Wyoming All MDs and DOs | N = 693 Survey Rural: 2003 Department of Agriculture RUCC codes 3 to 9 Outcome: Practicing in less-populated county in 2007 | Being raised in a rural area was associated with practicing in a less populated county (p < .05) in a multivariate analysis. Living in Wyoming as a child (p < .099) and attending medical school in a bordering state (p < .01) was not significant. There was no association with gender, being raised in a bordering state, completing an internship or residency in a bordering state, or plans to move out of state | There was no association with medical school location | N/A | N/A | N/A | Rural backgrounds and training independently predict practice location decisions.
Phillips, 2009^60^ | US allopathic medical students Physicians | N = 322,131 Analytic study Rural: RUCA codes Outcome: Rural practice in Rural Health Clinic (2001-2005) | Rural practice was strongly associated with being born in rural county (OR 2.35). Rural practice was associated with being male (OR 1.49), married (OR 1.47), age at graduation (OR 1.03). Rural practice was associated with plans to serve in underserved areas (RR 3.40) | Rural practice was associated with attending medical school in rural area (OR 2.93), career in family medicine (OR 2.65), as well as attending a public medical school (OR 1.66), community related medical school (OR 1.20), and experience in Title VII funded school (OR 1.11). Rural practice was associated with practice taking a rural (RR 1.9) or community health (RR 1.63) elective, family medicine clerkship (RR 1.44), experience with a Title VII school (RR 1.31), primary care residency (RR 1.22) | Rural practice was associated with NHSC loan repayment (OR 2.06), NHSC scholarship (OR 1.88), medical school debt $200-250K (OR 1.34), medical school debt $150-200K (OR 1.24), medical school debt $100-150K (OR 1.29), medical school debt $50-100K (OR 1.19), and medical school debt $1-50K (OR 1.06) | N/A | N/A | If rural–born students interested in serving the underserved also have rural training experience, it may have “multiples of effect”. Schools, residency programs, and medical education funders should consider this. Schools should institute a series of interview questions about rural and other underserved patients and should give these weight in acceptance. They could also become markers for targeted mentoring and training experiences.
Rabinowitz, 2012^61,76^ | MD graduates from Jefferson Medical College Physicians | N = 3006 Analytic study Rural: Rural county = 2007 Rural-Urban Density Typology (RUDT) Outcome: Practicing in rural area in 2007 | 3 predictors of rural practice (p<.001): growing up in a rural area, entering medical school with plans for rural practice, and entering medical school with plans to be a family physician. Of graduates with all predictors, 45% practiced in rural areas; of those with 2, 33%; of those with 1, 1%; and of those with 0, 12% practiced in rural areas. The RR for rural practice was 3.9 (CI 2.7-5.7, p < .001) for those with 3 predictors, 2.9 (CI 2.0-4.2, p < .001) for those with 2 predictors, and 1.8 (CI 1.2-2.8, p < .01) for those with 1 predictor. Medical students' specialty plans were strongly related to rural practice (p < .001) | N/A | N/A | N/A | N/A | Three factors known at the time of medical school matriculation have a powerful relationship with rural practice 3 decades later; relatively few students without predictors practice in rural areas, which is particularly significant given subsequent factors known to be related to rural practice – for instance, rural curriculum, residency location or spouse.
Renner, 2010^62^ | Colorado Healthcare professionals that participated in loan repayment program | N = 93 Survey Rural: ZIP code with RUCA designation above and including 4.0 Outcome: Practicing in rural care in 2007 | Rural providers were more likely to have gone to a rural high school than urban providers (38% vs 9%, p = .007) | N/A | 58% reported that salary was an important factor. Signing bonus, amount of loan repayment, and other incentives were less important. 42% reported the loan program had an important influence on the specific community they chose to practice | Rural providers rated location (83%), scope of practice (79%), and family fit with community (73%) as the most important factors. School opportunity for children were rated less important for rural providers | N/A | Loan repayment programs targeting rural Colorado usually enroll providers who would have worked in a rural area regardless of loan repayment opportunities, but are likely to play a role in provider's choice of specific rural community for practice.
Schiff, 2012^77^ | Physicians practicing in Hawaii who graduated from the University of Hawaii School of Medicine from 1993-2006. Physicians (all specialties) | N = 177 Analytic study Rural: O‘ahu considered urban; all other islands rural Outcome: Practicing in rural settings in Hawaii (1993-2006) | Hawaii-schooled physicians who attended rural high schools were 9× more likely to practice in a rural location than those who went to high school on a neighbor island (p<.0001) | No significant association between rural practice and primary care specialty (p = .09) | N/A | N/A | N/A | If the State of Hawaii wants to expand the physician workforce in the rural areas of Hawaii, recruiting more students from rural areas is an excellent path to take.
Shannon, 2011^78^ | Physician assistants in West Virginia who completed a rural rotation during clinical education Physician assistants (PAs) | N = 168 Analytic study Rural: ZIP code approximation of the RUCA code classification Outcome: Rural practice in West Virginia in 2005-2010 | Using gender, school, student evaluation of rural field experience, change in interest in rural health, confidence in community activities, confidence in meeting the needs of rural populations, rural high school hometown, rural practice intent, likelihood of West Virginia (WV) practice, only the variables rural high school hometown and likelihood of WV practice correctly predicted rural practice; 77% of students who predicted rural practice were in rural practice, 63% who did not predict it were in rural practice (p<.04) | N/A | N/A | Confidence in community activities, and confidence in meeting the needs of rural populations, did not predict rural practice | N/A | This study suggests moderate predictive validity of PA student reporting on rural practice and on West Virginia practice intent; such methods may have potential in prediction of the future rural PA workforce.
Smith, 2012^64^ | US PAs | N = 312 Survey Rural: < = 50,000 people Outcome: Rural setting for first practice in 2009 | Respondents who graduated from a rural high school and singles were significantly more likely to practice in a rural setting (both p<.05). No significant difference between rural practice and degree, race, gender, and age at graduation. Support of and for significant other was the most important factor for first practice location | Specialty distribution (primary care, specialty, other) was significantly different between urban and rural groups (p<.05) | N/A | N/A | Six factors emerged from factor analysis: hours of work/compensation , support of/for significant other, community and job amenities, educational resources/access to care, practice opportunities, and location | Respondents felt that support of and for the significant other was the most important factor in their first practice-location choice; recruiters may wish to pay closer attention to spousal opportunities and should not underestimate the impact of family in the decision about work location.
Snyder, 2014^79^ | PAs actively practicing in Indiana who graduated from 2000-2010, and had email addresses available. PAs | N = 157 Survey Rural: Respondent-defined Outcome: Location of initial job, location of current job (2000-2010) | N/A | 71% indicated educational dept had no influence on location of initial job | Males were more likely to perceive debt as influencing initial job location (χ^2^ = 11.65, p<.05). | N/A | 34% of urban PAs would have practiced in a rural area if they had received federal or state loan forgiveness for educational debt, 30% would have reconsidered. | This study provides evidence that debt may influence practice specialty and location choice. Further studies are needed to determine how gender might account for decisions to practice in certain specialties and location.
Stenger, 2008^80^ | Massachusetts physicians practicing in areas of the state designated as rural from 2004-2005 Practicing physicians | N = 160 Survey Rural: Non-metropolitan county designated non-urban by RUCA or population < 10,000 and population density < 500 people per square mile Outcome: Practicing in rural area in 2004-2005 | Most rural physicians (73.2%) had grown up in larger towns with populations of 10,000 or greater | N/A | N/A | Responses to why remaining in rural practice included feeling established with a strong sense of connection to patients and place, overall satisfaction with practice, and being in a great place to live | Factors associated with higher satisfaction included not feeling overworked (p = .043), or professionally isolated (p = .004), and being involved in practice (p = .045) and community (p = .036). | The findings reaffirm the importance of rural medical education opportunities in physician recruitment, retention, and practice satisfaction and indicate that a major source of physicians for rural and small town communities is physicians who have been raised in urban/suburban communities and who were trained outside of the region but who were prepared to live and to practice in rural and small town communities.
Whitacre, 2010^81^ | Medical students at Oklahoma State University College of Osteopathic Medicine Medical students between 1997-2002 | N = 190 Analytic study Rural: population < 50,000 Outcome: Rural practice location | Being raised in a rural area was associated with rural practice (p<.05) | Rural practice was associated with summer rural externship (p<.05), but not with all early clinical experiences | N/A | N/A | N/A | Programs implemented by an osteopathic school can influence where graduates choose to practice; programs taking place in both the 1st and 4th year of training have an impact on rural practice location, implying that students can be influenced both early and late in their medical school careers.
Zink, 2010^82^ | Medical students at 2 University of Minnesota campuses that did or did not participate in a rural training program Medical students | N = 3,365 Analytic study Rural: OMB's definitions; communities not listed were considered metropolitan if within 50 miles of an urban center, otherwise designated as rural Outcome: Rural practice in 2008 | In multivariate analysis, rural practice was associated with being raised in a rural community (OR 2.82, CI 2.1-3.79), but not with being raised in rural community and training in a rural program (OR.63, CI 0.35-1.15), or being raised in a rural community and Duluth campus (OR 0.56, CI 0.33-0.96) | Rural practice was associated with participating in a rural program (OR 4.62, CI 3.01, 7.07) and training at Duluth campus (rural focus) (OR 4.09, CI 2.81, 5.96) | N/A | N/A | N/A | RPAP and UMN-Duluth provide significant, complementary educational programs that lead more graduates to choose rural and primary care practices; efforts across the nation to address the crisis in rural primary care should build on these successful efforts.

Note: AMA = American Medical Association, AOA = American Osteopathic Association, CI = 95% Confidence interval, CME = Continuing medical education, DHHS = Department of Health and Human Services, DO = Doctor of osteopathic medicine, ED = emergency department, IMG = International medical graduates, MD = allopathic medical doctor, NHSC = National Health Service Corps, Ob-gyn = obstetricians and gynecologists, OR = odds ratio, OSHPD = Office of Statewide Health Planning and Development, PA = physician's assistant, PCP = primary care provider, OMB = Office of Management and Budget, RR = risk ratio, RUCA = Rural-Urban Commuting Area, RUCC = Rural-Urban Continuum Codes, UCSF = University of California-San Francisco

### Summary of Findings and Quality of Evidence for Key Question 2

This section summarizes the relative importance of individual factors that have been assessed in more than one study. The predictors are documented in the order of provider characteristics, provider training, financial aspects, and setting characteristics. Most studies asked or obtained responses regarding the demographic background of healthcare providers currently practicing in rural care. Half the studies addressed the training of healthcare providers (eg, graduating from a rural track school). A third of studies addressed financial aspects such as debt. About as many studies addressed aspects of rural communities or aspects of rural healthcare (eg, access to support from specialists).

The number of studies shown in Table 4 reflects how many studies have addressed the predictor variable regardless of the direction and strength of association with the outcome variable (entering rural healthcare practice). The table differentiates positive associations and results suggesting no associations. Results from multivariate analyses that control for confounding variables are listed first, followed by other results.

Table 4 Summary of Findings and Quality of Evidence – KQ2

Predictor variable | # studies | Results and consistency across studies | GRADE
Provider Characteristics
Proxy for rural background | 16 | [underlined: Association] Significant association with rural high school in multivariate analysis^72,78^ Significant association with being raised in rural area in multivariate model^81,82^ Significant correlation with nonurban high school or college^73^ Significant difference between groups due to rural high school^64^ Significant association with population of hometown^67^ Qualitative analysis suggests rural exposure via upbringing^69^ Significant difference due to rural childhood^70,77^ 70% of rural providers had a rural background^74^ Born in rural county increased odds (OR 2.65)^60^ Being raised in a rural area was associated with practicing in a very rural area vs rural area in a multivariate analysis^75^ A combination of growing up in a rural area, plans to practice in rural area, and plans for family medicine showed a positive association^61^ Higher proportion of attending rural high school in rural vs urban providers^62^ [underlined: No association] Majority of rural providers did not grow up in small town^65,80^ | High
Gender | 8 | [underlined: Association] Being male increased odds (OR 1.49)^60^ Slightly smaller number of female rural practitioners than in overall population^57^ Conclusion female physicians are less likely to practice in rural areas^66^ [underlined: No association] No association with gender in multivariate analysis^63,75,78^ No difference by gender groups^64,70,73^ | Very low
Family | 7 | [underlined: Association] Family ties reported as major reason^68^ Family/spouse reported to be a very important factor^70^ Significant association with location partner grew up in^73^ Proximity to family listed as motivation^74^ Significant association with having a child during or before med school^73^ Conclusion that support of and for significant other is most important factor^64^ [underlined: No association] Having children not associated with practice location^73^ Family obligation did not influence decision^74^ Job of spouse was rated as very important only by 28% of participants^62^ Spouse's job location was cited by only 30%^74^ | Low
Age | 3 | [underlined: No association] Age not associated with practicing in rural area ^72^ Age not associated with practicing in small town^63^ Age at graduation not associated with rural setting for first practice^64^ Age at graduation OR 1.03^60^ | Low
Marital status | 3 | [underlined: Association] Singles were significantly more likely to practice in a rural setting as first employment^64^ Being married increased odds (OR 1.47)^60^ [underlined: No association] Being married was not associated ^63,73^ | Very low
Race, ethnicity | 2 | [underlined: No association] Practicing in small town not associated with race^63^ Rural setting for first practice not associated with race^64^ | Low
International medical graduate (IMG) | 2 | [underlined: Association] IMGs comprise 22% of the clinically active workforce but contribute 19% to rural PCP workforce^58^ [underlined: No association] 13% of IMG compared to 18% DOs and 11% MDs are practicing in a rural location^57^ | Very low
Exposure | 2 | [underlined: Association] Qualitative analysis suggests exposure via recreation facilitates future rural practice^69^ Previous time spent in similar area was an important factor^70^ | Low
Training
Rural rotation in training or residency | 10 | [underlined: Association] Rural residency training showed an association in multivariate analysis controlling for rural upbringing^72^ Rural programs increase odds in addition to being raised in a rural community^82^ Rural residency trainees are 3× more likely to practice in rural areas^57^ Interviews suggest that exposure via education facilitates rural practice^69^ Rural clerkship and rural residency training were associated^73^ Optional summer rural externship increases probability^81^ Medical school in rural area OR 2.65, rural elective RR 1.53-1.93^60^ [underlined: No association] UMC graduates were not more likely to practice in rural areas than physicians who graduated elsewhere^63^ Medical school had discouraged rural practice for 40% of practitioners^74^ No association with medical school location^75^ No difference in rural rotation between rural and urban practitioners^70^ | Moderate
Primary care and family medicine focus | 4 | [underlined: Association] Primary care physicians are 2.4× more likely to practice in small towns than specialists in a multivariate analysis^63^ Rural family medicine residency graduates were 3× more likely to practice in rural care^57^ Specialty distribution (primary care, specialty) was significantly different between rural and urban groups^64^ Career in family medicine OR 2.65, family medicine clerkship RR 1.26-1.44^60^ Career in primary care OR 1.06, primary care residency RR 1.22-1.79^60^ [underlined: No association] No significant association with primary care specialty^77^ Career in primary care OR 1.06^60^ | Low
Osteopathic degree | 2 | [underlined: Positive association] 6% of workforce were DOs but 18% practice in rural care^57^ 4.9% of the workforce but contribute 10.4% to rural primary care^58^ | Low
Financial Aspects
Student loan or scholarship | 6 | [underlined: Association] 2^nd^ major reason was a loan or scholarship obligation^68^ Medical school loan repayment was correlated with rural practice^67^ NHSC loan repayment, NHSC scholarship, and debt increased odds^60^ Significant difference in ratings between urban and rural providers for importance of loan repayment^70^ Loan repayment program had an important influence on the community providers chose to practice for 42%^62^ [underlined: No association] Student loan debt was not a predictor of practicing in small towns^63^ The amount of loan debt was a less important factor^62^ For 71%, educational debt had no influence on initial job^79^ | Very low
Salary | 5 | [underlined: Association] Importance of income as a factor in practice location was different between rural and urban groups^71^ 58% found the salary an important factor^62^ Pay was correlated with selecting rural care^67^ [underlined: No association] Salary was not a predictor of practicing in small towns in a multivariate analysis^63^ Salary / signing bonus was rated as very important by only 24-28%^70^ | Very low
Setting Characteristics
Scope of practice | 4 | [underlined: Association] Broad scope of practice was cited as an important reason for general surgeons^73^ Scope of practice was important to 71% for healthcare providers^62^ [underlined: No association] Scope of practice was rated very important only by 30% of emergency department physicians^70^ Full scope of practice was important to 10% female physicians^74^ | Very low
Recreation activities | 3 | [underlined: Association] Access to amenities/recreation was rated as important for choosing practice location^70^ Recreation activities were rated as important by 58%^62^ Hunting birds and large game was associated with rural practice^73^ [underlined: No association] Currently hunting or fishing, fishing, and hunting small game showed no difference^73^ | Low
Lifestyle, small town life | 2 | [underlined: Association] Lifestyle was rated as very important^70^ Qualitative interviews identify desire for small town life as important^65^ | Low

The table also documents the quality of evidence (QoE) which influences how confident we are in making evidence statements based on the identified research. Key criteria were the number of available studies reporting on the variable of interest, confirmation in multivariate analyses, and conflicting results across studies.

#### Provider Characteristics

Regarding provider characteristics, a large number of studies have investigated a rural background (17 studies, high QoE) and have overwhelmingly shown a positive association with this factor. The result was also found in 2 multivariate analyses which control for confounders, suggesting that the finding is not better explained by other, confounding variables. However, 2 studies pointed out that of the identified providers in rural healthcare, most did not grow up in a rural community.^65,80^ We graded the evidence as high, despite the study design limitations and given that the factor cannot be analyzed in a strong research design such as RCTs.

Gender has been addressed in a number of studies but it remains unclear whether female healthcare providers are less likely to choose rural healthcare (9 studies, very low QoE). Study results were conflicting, may be confounded by changes over time, or may be provider group-specific.

Preferences of family, spouse, and children may be an important factor for choosing the geographic location (7 studies, low QoE). However, the existing evidence is somewhat conflicting, and the factor has not been addressed in multivariate analyses. Consequently, the relative importance of this factor, compared to rural upbringing for example, is unclear. There were conflicting results for marital status, with studies reporting increased odds, decreased odds, and no association (4 studies, very low QoE).

The association of provider race and ethnicity has been reported in 2 studies and both did not find an association. However, this is a common characteristic and a large amount of data may be available to answer this question which could not be considered (2 studies, low QoE of no association). Two studies investigated whether the country of origin of the healthcare provider can predict practice location but the evidence is unclear (very low QoE).

Two studies reported on the effect of exposure to rural areas, not specific to childhood experiences or provider training. Both suggested an association but the studies were not designed to quantify the strength of association and size of effect (low QoE).

#### Training

Regarding the effect of healthcare provider training on the geographic choice of practice, a large number of studies assessed the effect of rural tracks or a rural rotation as part of the healthcare provider training or medical residency (11 studies, moderate QoE). The choice to select a school with a rural track is likely to be influenced by an affinity to rural healthcare; however, 2 studies reported an association in addition to rural upbringing, lending support to the importance of this factor.^72,82^ But it should be noted that not all studies documented an association. We only considered evidence here from studies that looked at more than one predictor of rural practice; the success of training approaches is documented in KQ5.

Other characteristics addressed in more than one study were a primary care and family medicine focus which was associated with greater odds of practicing in rural care (5 studies, low QoE). The direction of causation for this association is unknown. Finally, 2 studies reported on differences between allopathic and osteopathic degrees in medicine, highlighting that osteopathic providers represent a smaller proportion of the workforce but contribute proportionally more to rural healthcare, but the statistical significance was not reported (2 studies, low QoE).

#### Financial Aspects

Regarding financial aspects, student loans have been investigated in several studies; however, the results indicate that it may depend on who was asked (8 studies, very low QoE). Student loans may be important factors for some healthcare providers, but even a large proportion of loan recipients indicate that they would have chosen rural care regardless of the program. The effect of loan forgiveness programs on rural recruitment and retention are documented in the next section (ie, KQ3).

Salary has been addressed as a factor in a number of studies but it remains unclear whether pay is a deciding factor for choosing rural healthcare (5 studies, very low QoE). Existing research shows conflicting results and the relative importance of the effect is not known.

#### Setting Characteristics

As mentioned above, there were relatively few studies addressing rural healthcare setting characteristics and their influence on the choice of the practice location (4 studies). Most studies that addressed these aspects reported on the scope of practice. Results were conflicting across studies and it is unclear whether an expected broader scope affects the geographic choice (very low QoE). Identified studies addressed different healthcare provider groups and results may vary by provider group. Unfortunately, there is not more than one study available that reported on the same group. Hence, the effects are not replicated and we could not evaluate any systematic differences between provider groups.

Three studies reported on recreation activities and there was some evidence suggesting that this factor affects the choice of practice (low QoE). However, one of the contributing studies reported conflicting results within the study, with associations depending on the exact predictor variable.^73^

Finally, the lifestyle in rural communities has been investigated in 2 studies. Both reported a positive association with the choice for practice. The variable has not been assessed in multivariate analyses and the strength of association in not known (low QoE).

We did not identify any VA datasets.

## KEY QUESTION 3 What interventions have been shown to increase rural healthcare provider recruitment?

This section describes the identified intervention evaluations directed at healthcare providers in rural communities. This includes programs for which healthcare providers that have completed their initial training period are eligible, rather than interventions exclusively designed for students and residents still in the process of completing their training. The evidence table lists evaluations of programs directed at recruitment as well as studies of programs directed at recruitment or provider retention in rural healthcare.

The included studies addressed effects of the J-1 visa waiver program and state-wide loan forgiveness programs. One of the evaluated programs addressed physicians,^83^ one physicians and nurses,^84^ and 3 a range of healthcare professionals including physicians, dentists, physician assistants, nurse providers, midwives, and mental health specialists.^62,85,86^ All studies were post-only study designs with no historic or concurrent comparator. Three relied, at least in parts, on the responses of surveyed participants; the response rate ranged from 55 to 80%.

The J-1 Visa Waiver Program has been in place since 1994 and was expanded in 2002; it allows states visa waiver slots on an annual basis. The evaluation assessed the effects of the program on the state of Washington where selected physicians are obligated to work for an approved employer for 3 years for primary care physicians and 5 years for specialists.^83^ The loan forgiveness programs were established to increase the number of healthcare providers in rural^85^ or rural or underserved areas.^62,84^ One study reported on all state-wide recruiting interventions for West Virginia.^86^

All evaluations assessed state-wide effects. Studies reported on the uptake of the program, the percentage of physicians fulfilling their obligation (eg, 3 years of practice at a designated site), and other results relevant to recruitment and retention.

The evidence table summarizes the studies and evaluated programs.

### Summary of Findings and Quality of Evidence for Key Question 3

In addition to the small number of identified evaluations we did not identify studies reporting on the same outcome within the recruitment or the retention outcome category. Hence, no summary of findings table was completed and results are narratively described.

One of the identified evaluations was a J-1 visa waiver program evaluation on state level. Of all J-1 visa waiver placements in the study, about one-third were in rural areas. The J-1 visa evaluation reported that 53% of physicians did not complete their obligations. But of the respondents who had completed commitments, 84% remained a median of 23 months longer than required.^83^

The Minnesota loan forgiveness program highlighted that 86% of surveyed physicians continued medical practice at their sponsoring healthcare facility.^85^ The Colorado program reported that 57% of respondents worked in rural communities. The evaluation also highlighted that 74% of J-1 visa waiver recipients were already working in or intended to work in an eligible community when they were made aware of the program. Furthermore, 38% of those working in rural communities reported loan repayment as being important to retention.^62^ The Oklahoma assistance program reported that of those recipients whose obligated practice location was rural, 84% were practicing in rural areas and 28% of those who fully completed their service obligation were practicing in rural areas.^84^ An evaluation of Virginia Division of Rural Health and Recruitment programs stated that 80% of placed providers have remained at their initial placement site upon completion of their obligation.^86^

We did not identify any VA datasets.

## KEY QUESTION 4 What interventions have been shown to increase rural healthcare provider retention?

We did not identify any evaluation of a provider intervention that was exclusively directed at retaining fully-trained providers practicing in rural healthcare. All other intervention studies aimed at providers are included in the evidence table for KQ3 (interventions to improve recruitment, alone or in combination with improving retention). Studies examining interventions for providers in training are discussed in the KQ5 section.

### Summary of Findings and Quality of Evidence for Key Question 4

Of the small number of identified provider intervention studies (see evidence table 5), some reported on the outcome retention. The J-1 visa evaluation and loan forgiveness programs reported that 80% or more of respondents remained longer than their required obligations, although only one study reported the duration.^83,85,86^

Table 5 Evidence Table – KQ3 (Provider Recruitment Interventions)

ID | Region Providers | Participants | Intervention | Study design Definition of rural | Recruitment results | Retention results | Authors' conclusions
Kahn, 2010^83^ | Washington state J-1 visa waiver physicians | 77 of 141 returned survey (response rate 55%); 155 physicians began J-1 waivers in Washington state between 1995 and 2003; addresses of 141 were located | Under the 1994 Conrad J-1 Visa Waiver Program (updated and expanded in 2002), each participating state is allocated 30 visa waiver slots annually to administer through its state health department. After states recommend physicians for visa waivers, these doctors are obligated to work for an approved J-1 waiver employer for the duration of their commitment period, which in Washington state is 3 years for primary care physicians and 5 years for specialists | Post-only study Rural: ZIP code Version 1.11 of RUCA Codes (based on 1998 Census commuting data and 1988 ZIP codes) to classify addresses and Version 2.0 (based on 2000 Census commuting data and 2004 ZIP codes) to classify the current work addresses of the 127 physicians we located; 10-point scale | 155 began program, 68% practiced primary care; 37% completed their obligations in rural areas. Of these, 47% practiced in large rural cities/towns, 32% in small rural towns, and 21% in isolated small rural towns | Of 141 tracked physicians, 23% are still working for their assigned employer; of respondents who had completed commitments 84% remained longer than required (median 23, mean 25 months, range 0-120); the average RUCA rating for original J-1 waiver locations was 3.02 (higher numbers indicate more rurality), whereas the average current employment RUCA category was 1.51; physicians appear to have moved toward more urban areas (p<.001) | In Washington state, the Conrad Program has increased the number of physicians in underserved areas who frequently stay beyond their obligations. The significant movement away from rural areas for postobligation employment, however, highlights the long-term need to continue state efforts to recruit physicians to these areas.
No Author, 2007^85^ | Minnesota Physicians, NPs, nurse midwives, nurse anesthetists, advanced clinical nurse specialists, physician assistants, dentists, pharmacists, allied health and nursing faculty, nurses | 564 participants from 1990 to 2007, 405 surveyed, 73% response rate | In 1990, the Minnesota State Legislature created and funded a program to recruit physicians to practice in rural Minnesota. Since then the program has expanded to assist 564 practitioners in rural Minnesota or other high-need locations. After almost 17 years of operation and growing from an annual state appropriation of $320,000 to $1.295 million in 2007, the Minnesota Loan Forgiveness Programs have served over 300 healthcare facilities and educational institutions throughout the state. In the past 7 years, Minnesota has invested $7.789 million in the Loan Forgiveness Programs | Post-only study Rural: Designated rural sites for areas outside metropolitan counties (Hennepin, Anoka, Ramsey, Dakota, Washington, Carver, and Scott) and excluding Rochester, Moorhead, St. Cloud, Duluth, and Mankato | >240 responders have chosen rural or high-need settings in the past 8 years as a result of the program; 44% of respondents said it was important to very important in influencing their decision to choose primary medical practice (70% in 1999). Distinct decline in physician applications in 2007 (1/3rd fewer applications than 2006, > 50% reduction since 2003 | 86% of respondents continued medical practice at their sponsoring facility (placement site) after completing their service obligation | The Loan Forgiveness Programs are successfully meeting their program goals and increasing the number of healthcare providers and educators in rural Minnesota and specialty locations.
Renner, 2010^62^ | Colorado Healthcare professionals (39% physicians) | 97 respondents (response rate 80%) | Colorado health professional loan repayment program (CHPLRP): began in 1992, rewards physicians, dentists, PAs, NPs, certified midwifes and mental health specialists with up to $35,000 per year of educational loan repayment for working in any rural or urban HPSA in Colorado with minimum 2-year commitment. Colorado Rural Outreach Program (CROP): created in 1998, rewards all types of healthcare professionals (including but not limited to physicians, NPs, PAs, nurses, mental health services, dental health services, and allied health professionals up to $10,000 per year for educational loan for up to 3 years. Provider must work in a rural community in Colorado to be eligible and program requires 1 year service commitment. Dental Loan repayment program: began in 2002, provider must work with underserved populations in either rural or urban areas to be eligible | Post-only study Rural: RUCA ZIP code designation above and including 4.0 | 57% of respondents worked in rural communities. Of rural participants, 74% were working in or intended to work in an eligible community when they were made aware of the loan repayment program. Of those planning to work in a rural community regardless of loan repayment option, 42% reported the program had an important influence on the specific community they chose | Of the participants already working in rural communities, 38% reported loan repayment as being important to retention. Of rural participants, 22% cited the desire for a higher income as an important reason to leave their communities regardless of loan repayment | Loan repayment programs enroll providers who would have worked in a rural area regardless of loan repayment opportunities, but are likely to play a role in provider's choice of specific rural community for practice; they also appear to influence rural provider retention, though financial concerns are generally less influential for non-retained rural providers than are family preferences and professional dissatisfaction.
Wheeler, 2009^84^ | Oklahoma Graduates of Oklahoma State University Osteopathic College | 333 | The Physician Manpower Training Commission (PMTC) was established by the Oklahoma state legislature in 1975 with the primary mission of increasing the number of physicians and nurses in rural and underserved areas of the state | Post-only study Rural: N/A | PMTC has provided financial assistance to 333 graduates, 30 graduates opted to repay the loan and terminated their contract, resulting in 303 program completers since 1978. Of all program completers, 83% continue to practice medicine in Oklahoma; 28% of these are practicing in rural areas of the state. 62% of alumni who participated in PMTC's funding programs are practicing in rural areas | 51 program completers completed their contractual practice obligation but are either no longer in active practice or have left the state. For those whose obligated practice location was in a rural area, 84% are currently practicing in a rural location | Clearly, PMTC programs have been successful in the recruitment and retention of graduates to rural practice in Oklahoma.
Wheeler, 2013^86^ | West Virginia Primary care physicians, sub-specialists, specialists, physician assistants, and family nurse practitioners | not defined | The Division of Rural Health and Recruitment administers several financial incentive programs: the National Health Service Corps loan repayment program (primary care physicians, physician assistants, nurse practitioners, certified nurse midwives, general and pediatric dentists, dental hygienists, behavioral healthcare providers, nursing faculty, and practicing nurses; 2-year service obligation); State Loan Repayment (10 providers per year; physicians, nurse practitioners, dentists, physician assistants, pharmacists; obligation to work 2 years in rural West Virginia; recipients eligible to reapply for additional 2 years); Recruitment & Retention Community Project (for facilities located in a federally designated MUA/MUP; one-year commitment, with the employer matching the award, for a total of $20,000.00); the J-1 Visa Waiver Program (communities unable to recruit a US citizen to provide healthcare are allowed to recruit a foreign physician); Recruitable Community Program (promoting volunteerism). | Post-only study Rural: West Virginia is the second most rural state in the nation, and the only state that is located entirely within Appalachia | Through these various programs, the Division of Rural Health and Recruitment has placed a total of 154 NHSC providers; 52 SLRP providers; 47 RRCP providers; and 94 J-Visa physicians since 2008 | Currently, 80% of these providers have remained at their initial placement site upon completion of their obligation | The Division of Rural Health and Recruitment works diligently to alleviate some of those shortages and to strengthen the healthcare safety net in West Virginia, and utilizes the most up-to-date and relevant provider recruitment and retention strategies available.

RUCC = Rural-Urban Continuum Codes, RUDT = Rural-Urban Density Typology, RR = relative risk, OR = odds ratio

## KEY QUESTION 5 What is the efficacy of current rural-specific resident and healthcare profession student training and education efforts?

This section documents the identified evaluations aimed at resident and healthcare profession student training. All identified studies are documented in the evidence table; the summary of findings section synthesizes results across studies.

Thirteen studies assessed the training of medical students, while 9 examined the training of residents, and one a combination. The most common resident specialties were family medicine and general surgery, with one study each examining residents in emergency medicine,^87^ psychiatry,^88^ and across all specialties.^89^

The majority of the included studies evaluated a single training program at one institution. Rabinowitz et al reported on multiple cohorts at the Jefferson Medical College, Pennsylvania.^90,91^ One study reported on different programs at the University of Minnesota,^82^ while another study reported the effect of different components of a program.^92^ Total numbers of participants (including controls) ranged from 7^93^ to 3,365.^82,94,95^ The studies utilized internal records or internally distributed surveys for determining practice locations after graduation. Four studies used external records such as the AMA Masterfile or state licensure records.

The majority of training programs evaluated consisted of embedding a student or trainee in a rural community for all or part of their medical training. Experiences ranged in duration from 4 weeks^93^ to 5 years.^96^ Studies of individual training programs reported capacities ranging from 2^29,97^ to 60^98^ trainees per year.

Studies evaluating multiple training programs reported on sample sizes ranging from 123^99^ to 322,131^60^ participants. Few of these multiple-institution studies included details for the year of graduation or completion of training. The majority of these studies discerned practice locations from publicly available data such as the AMA Masterfile, while one study used data reported by the individual training programs examined ^98^ and one used a survey distributed by the authors.^87^ Studies evaluated rural tracks across medical schools,^98,99^ assessed resident training in Critical Access Hospitals or Rural Health Clinics, compared 3 different rural programs that combine preferential admissions of students likely to practice in rural areas with a rural curriculum,^91^ assessed the effect of the expansion of medical schools on rural healthcare or Title VII funding,^100^ evaluated rural rotations for emergency medicine residents,^87^ and assessed which US medical schools provide physicians for the Appalachian region of the US.^101^

Most studies reported on the outcome of recruitment of graduated trainees to a rural area, and 5 studies reported on retention in these areas. One study reported only on matriculation of medical students from rural backgrounds.^100^ In studies that formally defined “rural,” the designation referred to federal taxonomies such as RUCA codes or RUCC. In 7 studies, the designation of an area as rural was determined by the training program or was not specifically discussed. Only 6 studies included a comparison or control group against which to compare outcomes, with the rest of the studies reporting only on the group of trainees undergoing the rural-specific training.

The evidence table summarizes all identified studies contributing to this key question. The table includes information about the training programs, outcomes, and the authors' conclusion from the study. The table lists single institution studies first, followed by evaluations across multiple training institutions.

Table 6 Evidence Table – KQ5 (Provider Training Evaluations)

ID | Location Capacity | Students N Data source | Program description | Study design Definition of rural | Recruitment results | Retention results | Other results | Authors' conclusion
Single-institution Program Evaluations
Antonenko, 2009^96^ | North Dakota University of North Dakota (UND) School of Medicine and Health Sciences Capacity: 1986-2008 = 44 residents | General surgery residents N = 44 Internal records | General surgery residency started in 1982, first graduates in 1986. ACGME-required rotations include anesthesiology, pathology, plastics, orthopedics, ears, nose and throat, and urology, pediatric surgery and trauma surgery as 4^th^-year residents; 1 month in each of first 2 years at Belcourt Indian Health Services Hospital on on the Turtle Mountain Indian reservation in central North Dakota | Post-only Rural: N/A | 47% of graduates continue to practice in rural areas; of those pursuing fellowship training, 16% practice in rural areas (58% general surgeons who did not take fellowship training practice in rural sites) | N/A | N/A | The program continues to provide the best training consistent with the practice requirements of its graduates – particularly those who chose to practice in smaller communities and rural sites.
Bonham, 2014^88^ | University of New Mexico (UNM) New Mexico Capacity: 60 residents from 1991-2010 | Psychiatry residents N = 60, 37 responded to survey (62 % response rate) Internal database | The UNM Rural Psychiatry Residency Program (UNM RPRP) was developed in 1991 to improve residency education about rural mental health and to increase the number of psychiatrists in rural and underserved communities. All trainees participate in an 8-week seminar about rural mental health, cultural competence, and public mental health systems. 1/3 of residents elect to participate in community site visits in PGY-2 and PGY-3 years. During the PGY-4 year, residents work in community settings for 2 days a week throughout the year. Residents return each week to the university for didactics and to see their psychotherapy patients and supervisors. Participants receive sponsorship to attend the meeting of the Rural and Community Psychiatry Network of New Mexico. This network is designed to support efficacy and retention of providers in rural communities by reducing the experience of provider isolation. At the meeting, residents meet psychiatrists who practice in rural communities and begin to build the personal and professional networks on which they will rely as professionals. | Post-only Rural: Metropolitan (continuously built-up areas of 50,000 or more), large rural town (10,000–49,999), small rural town (2,500–9,999), or isolated small rural area (outside of urban areas or urban clusters). | 37% of program graduates were practicing psychiatry in rural communities compared to 10 % of the graduates in the traditional program. Of all graduates who were currently practicing in rural communities, 75% were practicing in large rural towns, 20% in small rural towns, 6% in isolated small rural areas | N/A | N/A | Purposeful and well-coordinated educational opportunities situated in rural community health clinics can address some of the barriers for recruiting and retaining psychiatrists in rural areas. Practical skill-building at the individual, agency, and system level is integral in training psychiatrists for work in these communities. In particular, the use of telepsychiatry emerged as an important practical application for the provision of rural mental healthcare.
Crane, 2014^102^ | North Carolina Hendersonville Family Medicine Residency Program Capacity: 37 graduates from 1999-2010 | Family medicine residents N = 37 Internal database | Rural-track training program to address the growing shortage of primary care physicians in rural North Carolina. Designed to develop successful rural health physicians | Post-only Rural: N/A | 65% graduates practice in rural communities | N/A | 60% work in a full or partial health professional shortage area | Rural-track training programs have generally been more successful than traditional family medicine residencies in placing graduates in rural or underserved practice settings. Our program contributes to improving access to care and new models of care and warrants further investigation in how training can be scaled to address North Carolina's continuing shortages of rural primary care physicians.
Crump, 2013^103^ | University of Louisville, Kentucky Trover campus in Madisonville (ULTC) versus main campus in Louisville Capacity: 6-10 medical students per year | Medical students N = 1391 AMA Masterfile linked to medical school graduation list | After completing their first 2 years of basic sciences, students move to Madisonville and complete all required clinical rotations and most electives there or in the smaller surrounding communities. The small class size provides a personal connection between faculty and student. Students are based within a rural integrated health system with a 400-bed hospital staffed by 80 primary and secondary care physicians. The system includes 10 satellite clinics within a 30-min drive that are in towns of 4,000-8,000 that host portions of clinical rotations. Trover students participate in the same lectures as the Louisville students via live video connection and all curriculum elements, teaching materials, and evaluation systems are identical. Clinical rotations on the ULTC provide the opportunity for 1-on-1 learning with an experienced clinician preceptor. On ∼1/3 of rotations, a family medicine resident is on the teaching service as well. All 3rd-year students regardless of rotation meet for small-group, problem-based learning sessions using the iterative process 2×/month. A longitudinal teaching skills program assists the community-based faculty in guiding the students through their required clerkships | Comparative study Rural: RUCC, nonmetropolitan RUCC codes as a surrogate to identify rural/small-town practice | 55% of ULTC graduates chose nonmetropolitan practices compared with to 9% of Louisville graduates (p<.001) | N/A | N/A | These data support the value of a small regional rural clinical campus in optimizing the affinity model to place rural students into rural practice. The ULTC students showed equivalent adjusted test scores and slightly narrowed the gap in unadjusted USMLE scores compared with the main campus students.
Deveney, 2009^29,97^ | Oregon Health Sciences University Grants Pass, Oregon Capacity: 2 4^th^-year residents per year | General surgery residents N = 70 Internal results | Grants Pass has a population of 25,000 with a 125-bed hospital, residents are placed for a year-long 4^th^-year rotation | Post-only Rural: Site with population <50,000 | Graduates are more likely to practice in a site of population <50,000 (p = .02) than graduates before the program | N/A | N/A | The need for more general surgeons who are prepared and willing to serve rural communities is well-recognized. Based on our experience over the past 7 years, we believe that residents will benefit from a training program that provides extensive exposure to procedures unique to a rural practice.
Glasser, 2008^68,104,105^ | Rockford, Illinois Rockford, Illinois Capacity: 159 graduates from 1993-2007, typically admits 15-20 students | Medical students N = 216 Internal database | The curriculum is based on observations of other rural medical education programs. A key concept is the integration of clinical medicine and population health. PY1 topics: population-based approaches to rural healthcare, agricultural hazards and farm safety, health resources in rural communities, rural mental health issues, and community-based rural health research. PY2: chronic disease management, rural clinical cases discussion, complementary and alternative medicine, rural health issues, and community-oriented primary care (COPC). PY3: introduction to Community Project Resource Book and Community Structure Project, perspectives on practice location and practice arrangement decisions, ethical dilemmas, coding and optimized reimbursement, the IRB process, and COPC work sessions. In years 1 and 2, there are also field trips and special events (eg, “Southern Exposure;” the “No Harm on the Farm” tour; and the Illinois Rural Health Association meeting) to provide students with the opportunity to observe and participate in rural health communities and organizations. The course grades are part of the final medical school transcripts. The 3^rd^-year curriculum serves as preparation for the 4^th^-year, 16-week preceptorship in a rural community. Students select 1/25 rural communities. For each site, the local hospital has agreed to provide room and board for the student as well as a primary care physician to serve as preceptor. | Post-only Rural: RUCA | 67% of graduates practice primary care in towns of 20,000 people or fewer or practice in communities classified as RUCA codes 4 and higher. 2010 publication reports 70% practice in rural area. 2013 publication reports 61% practice in towns of 20,000 people or less, with 23% practicing in towns of 5,000 or less, 56% practice in RUCA code 4 or higher areas | 82% have stayed at their original practice site, 8 graduates with 3 or more years in primary care practice have relocated to rural communities | N/A | Our program can serve as a model at many levels, including recruitment, collaboration, curriculum, and retention. Future challenges include recruiting students from the growing number of rural minority populations, expanding the number of program slots, and integrating the program with other health professions to address the needs of rural populations.
Kallail, 2010^106^ | Kansas N/A Capacity: 14 students per year | Medical students N = 104 Internal database | Applicants must be Kansas residents with significant experience living in a rural Kansas community. They must demonstrate intellectual promise, the intention to practice medicine in rural areas of Kansas, and a commitment to service by exhibiting the dedication and compassion necessary to be a competent and caring physician. The application and selection process is similar to regular medical school admissions. The primary difference is that Scholars applicants interview after their undergraduate sophomore year and enter medical school 2 years later after successful completion of program requirements. Each program participant must demonstrate achievements in academic programs and a significant, informed interest in rural healthcare. Scholars are assigned a rural primary care physician mentor beginning in the junior year of college. The mentors are usually from Scholars' hometowns or nearby. Scholars shadow for a minimum of 200 hours over the 2 years. They write 4 case reports and write a paper on a population-based, community health issue. | Post-only Rural: Based on population density (either frontier, rural, or dense rural) | 63% of graduates practice in rural, non-metropolitan communities (11/12 in Kansas); of those in rural communities, 11 are family physicians, and 1 is a general surgeon | N/A | 84% practice in either a rural or urban underserved community | As one component of the effort to provide physicians for Kansas, our program showed beneficial outcomes for attracting applicants who want to practice in rural or other medically underserved communities and who maintain that interest over the long process of medical education. The designation of medical school positions for 14 Scholars in Rural Health enhances the likelihood of success for maintaining a pipeline of physicians for rural Kansas.
Mason, 2012^63^ | Mississippi N/A Capacity: N/A | 1990-1999 UMC graduates practicing in Mississippi N = 927 Mississippi State Board of Medical Licensure | University of Mississippi Medical Center (UMC) is the only medical school in the state and Mississippi is one of the most rural states in the nation; about half of new practicing physicians come from UMC's graduating classes | Post-only Rural: N/A | UMC graduates are not more likely to practice in rural, small towns, or geographically isolated areas in Mississippi than physicians who graduated elsewhere | N/A | Primary care physicians are 2.4 times (P<.001) more likely to practice in small town areas than specialists, all else being equal | Health educators and policy makers should consider broadening UMC's enrollment policies and greater emphasis should be placed on recruiting physicians.
Nash, 2008^93^ | University of Texas (UT) Medical Branch at Galveston Weimer, Texas (138 miles from university) Capacity: 2-3 residents | Family medicine residents N = 7 Internal records | UT Galveston implemented a rural training track (RTT) in 1998. Residents spend 4 weeks living and working in a rural Texas community supervised by clinical family physician faculty. In 2000, the RTT was expanded to a longitudinal rural curriculum (spending 28 weeks in rural communities) | Post-only Rural: N/A | 86% of graduates entered practice in rural areas | N/A | N/A | Although the program is small, the RTT has shown proportionally impressive success with graduates choosing rural practice in Texas.
Quinn, 2011^92^ | University of Missouri School of Medicine Rural communities in Missouri Capacity: Preadmission program: up to 15 students/year. Summer Community Program: 20 to 30 students/year. Rural Track Clerkship: 20 to 35 students/year. Rural Track Elective: 5 to 7 students/year. | Medical students in their 2^nd^-4^th^ years N = 344 MUSOM Alumni Association database, the National Residency Match Program, and the American Board of Medical Specialties, as well as information gleaned from Internet searches and from personal correspondence with program participants | The program has 4 facets: 1. Preadmissions program for rural students (Rural Scholars). A cooperative effort between 6 designated institutions and the MUSOM, designed for students from rural backgrounds. Rural Scholars are accepted into the MUSOM, conditional on academic achievements, professional conduct, and participation in required activities. Program activities include biannual retreats, mentoring relationship with a rural physician, and community service. Rural Scholars also participate in the Summer Continuity Program, the Rural Track Clerkship, and the Rural Track Elective. 2. Summer Community Program for rising 2^nd^-year students. Students work closely with physicians practicing in smaller communities for 4-8 weeks. 3. Rural Track Clerkship (RTC) Program for 3^rd^-year students. The RTC Program offers all 3^rd^-year medical students the choice of completing 1-3 of their 7 required core clinical clerkships in rural training sites. Students live in the community while completing their clinical rotations. 4. Rural Track Elective Program for 4^th^-year students. Medical students may choose to complete a variety of required monthlong primary care or specialty electives at 1 of 10 community-based rural clerkship sites. Beginning with the graduating class of 2013, Rural Scholars are required to take at least 1 elective. | Post-only Rural: RUDT, population density thresholds of the US Census Bureau's classification system, Office of Management and Budget's urban population nucleus requirements, and other criteria to classify counties as “rural,” “mixed rural” | Preadmission Rural Scholars program: 50% report first practice location to be rural or mixed rural. Only in the Rural Track Clerkship: 64% first practice location rural or mixed rural. Rural Track Clerkship + Summer Continuity Program or Rural Track Elective: 56% first practice location rural or mixed rural; Any aspect of the Rural Track Pipeline Program: 57% first practice location rural or mixed rural | N/A | N/A | The longitudinal program successfully recruits students for rural and primary care practice to address the healthcare needs of Missouri.
Rabinowitz, 2011^90,107^ | Jefferson Medical College -Pennsylvania 3^rd^-year family medicine clerkship in rural location, and senior outpatient subinternship in family medicine Capacity: 104 PASP graduates between 1992 and 2002 | Medical students in Jefferson Physician Shortage Area Program (PSAP) versus those that did not participate in PSAP N = 2394 Jefferson Longitudinal Study (JLS) of Medical Education database from 1992-2002; 2007 alumni database | PSAP initiated 1974 at Jefferson Medical College. Recruits and selectively admits medical school applicants who have grown up in a rural area and who are committed to practicing family medicine in a rural area, especially Pennsylvania. During medical school PASP students have a family physician faculty mentor, take required 3rd year family medicine clerkships in a rural location, take their senior outpatient subinternship in family medicine (usually rural location) and receive a small amount of additional financial aid (usually in form of repayable loans). On completion of medical school, PSAP graduates are expected to complete family medicine residency and practice family medicine in a rural location of their choosing, although no formal mechanism exists to ensure compliance. | Comparative study Rural: Rural-Urban Density Typology (RUDT), % rural or urban, population in urbanized areas, population density Alternate definition: rural counties are those where less than 50% of the population live in an urbanized area (ie, a densely settled territory with 50,000 or more people) | 43% of PSAP graduates were currently practicing in a rural area (compared to 15.8% of non-PASP graduates, RR 2.7, CI: 2.1-3.5, p < .001). PSAP graduates were almost 10× more likely to combine family medicine with practice in a rural area (32.0% vs non-PSAP peers 3.2% (RR 9.9, CI 6.8-14.4; p < .001); > 1% of PSAP graduates were practicing in 18 of the state's 48 rural counties, whereas no rural county had even 0.3% of non-PSAP graduates | N/A | When applying the secondary definition of rural, the pattern of results were similar; but the absolute % were lower. Women PSAP graduates were >2× as likely as non-PSAP women graduates to practice in rural areas (RR, 2.6; CI, 1.6–4.2), similar to the PSAP impact on men | Despite major changes in healthcare in recent decades, Jefferson's PSAP continues to represent a successful model for substantially increasing the supply and distribution of rural family physicians. Especially with the forthcoming expansion in health insurance, access to care for rural residents will require an increased supply of providers. graduates.
Rabinowitz, 2013^108,109^ | Jefferson Medical College, Philadelphia, PA N/A Capacity: 1937 graduates from 1978 to 1986 | Jefferson medical school graduates N = 1937 graduates from 1978 to 1986 Jefferson Longitudinal Study | The Physician Shortage Area Program (PSAP), which began in 1974, recruits and selects medical school applicants that have grown up or lived in a rural area or small town for a substantial portion of their life after college and who were committed to practicing family medicine in a similar area. During medical school, PSAP students received faculty mentorship and career support and they completed their required 3rd-year, 6-week family medicine clerkship in a small town. During their 4^th^ year, most PSAP students took a preceptorship in a rural location. Upon graduation, PSAP students were expected to take a family medicine residency and practice family medicine in a small town or rural area, although there is no mechanism to ensure compliance. | Post-only Rural: County not designated as a standard metropolitan statistical area | N/A | Of 37 PSAP graduates who originally practiced rural family medicine, 70% were still practicing family medicine in the same rural area (compared with 46% of non-PSAP graduates) (p = .02) | N/A | This study provides additional support for the substantial impact of medical school rural programs, suggesting that graduates of rural programs are not only likely to enter rural family medicine but to remain in rural practice for decades.
Ross, 2013^110^ | Klamath Falls, Oregon Cascades East Family Medicine Residency Program; Sky Lakes Medical Center Capacity: 76 residents completed training from 1994 - 2009. | Family medicine residents N = 76 graduates sent survey. Response received from 62 (> 82% response rate) Survey | 3-year family residency training program in Klamath Falls (population ∼42,000) at 96-bed, nonprofit community hospital (only Oregon residency program outside metropolitan Portland area). AAFP notes this training site to be the most rural and remote training site in the nation and it is supported by the smallest community hospital. The program's main goal is to produce full scope of practice family physicians to enter rural practice | Post-only Rural: Rural practice = populations <25,000, >25 miles from major centers | 60% of graduates initially enter practice in communities of <25,000 population and 45% practice in towns of <10,000; 63% of graduates first practiced in HPSAs | 37% remained in very rural locales of <10,000 population; 50% of all graduates since 1994 remain in rural settings; 52% of graduates that first practiced in HPSAs remain in those areas, with 45% delivering care at FQHCs or RHCs | Of 25 graduates who practiced in >1 location since graduation, 18% moved to larger centers, 11% moved to towns of the same size, and the remaining 11% moved to smaller population centers | Family medicine residency programs of 3 years duration, located in small community hospitals, would seem to be ideal settings for training future rural physicians. The outcomes substantiate this conclusion and show that rural residency graduates tend to serve small communities, often the one where they first enter practice, for an extended period.
Whitacre, 2010^81^ | Oklahoma Oklahoma State University Capacity: N/A | Medical students N = 190 Internal data | Osteopathic school program designed to promote rural location: Summer rural externship (optional) – observe local physician 30-35 hours per week during summer following 1^st^ year of medical school. Early clinical experience (optional) – 5-day tour of different physician offices across the state. Community clinical clerkship (mandatory) – 1-month rotation during 3^rd^ year in medical school. Rural clinic clerkship (mandatory) – 1 month rotation during 3^rd^ year in medical school. Community hospital rotations (mandatory) – 2 months during 4^th^ year of medical school. | Post-only Rural: Community with population <50,000 | 30% of graduates chose to practice in a rural location. In regression models, the optional summer program increased probability of locating in a rural area by about 24% | N/A | N/A | Programs implemented by osteopathic school can influence where graduates choose to practice. In particular, programs taking place in both the 1^st^ and 4^th^ year of training have an impact on rural practice location.
Zink, 2010^82,94,95^ | University of Minnesota; Duluth and Twin Cities campuses Minnesota Capacity: Duluth average class size = 60 students; RPAP average class size = 33 students | Medical students N = 3365 RPAP and Duluth internal database matched to AMA Masterfile | Duluth Campus: During the 1^st^ year of medical school, each student is assigned to a practicing family physician. Students meet with their preceptors 10× per year. Sessions expose students to the variety of activities (eg, hospital rounds, clinic practice, nursing home rounds). At the end of the 1^st^ year and again for 3 sessions during the 2^nd^ year, students live with a rural preceptor and his or her family for 3 days and are exposed to the physician's everyday working environment and lifestyle. These communities are located in Minnesota and western Wisconsin, and many are contiguous to or located in medically underserved areas. Faculty meet with students 3×/year to discuss the students' experiences. RPAP (Rural Physicians Associates Program) Students spend 9 months in a rural community under the mentorship of a primary care preceptor. RPAP developed its training model in the early 1970s. Students experience the full scope of primary care and become part of the small-town community. They follow patients over time, acquire hands-on experience, and complete specialty rotations. In recent years, online learning modules and class discussions fostering connectivity and learning across sites were incorporated. | Comparative study Rural: Office of Management and Budget's definitions of metropolitan and nonmetropolitan populations. Communities that were not listed were considered metropolitan if within 50 miles of an urban center, otherwise designated as rural | 43% of RPAP graduates are in rural settings and 28% of Duluth campus without RPAP. Logistic regression demonstrated that the RPAP (OR 4.62 (3.01-7.09, p<.001)) and UMN–Duluth (OR 4.09 (2.81-5.96, p<.001)) experiences are additive for the outcome of graduating students who chose rural practice | N/A | N/A | RPAP and UMN–Duluth provide significant, complementary educational programs that lead more graduates to choose rural and primary care practices. Efforts across the nation to address the crisis in rural primary care should build on these successful efforts. Both are achieving their missions, and the programs are complementary.
Evaluations across Multiple Training Institutions
Baker, 2012^101^ | West Virginia N/A Capacity: N/A | Medical school graduates practicing in Appalachia N = 44,894 2009 AMA Masterfile | US medical schools providing physicians for the Appalachian region of the US | Post-only Rural: rural or urban according to 1999 federal metropolitan and nonmetropolitan designations | 10 schools produced 50.5% of all US medical school graduates from these years who practiced primary care in rural Appalachian counties. The West Virginia School of Osteopathic Medicine ranked 1^st^, followed by the University of Pikeville Kentucky College of Osteopathic Medicine and the University of Alabama School of Medicine. 6/10 are located not just in Appalachian states but actually in Appalachian counties | N/A | N/A | Physicians practicing in Appalachia are largely graduates of medical schools in or near the region. New schools being developed in the region may help reduce its continuing physician shortages.
Deutchman, 2013^98^ | 35 US medical schools with established rural tracks or rural tracks in development, 38 rural track Capacity: The number of students participating in each RT ranges from 4-60, with the majority representing 5% to 10% of each class at that institution. | MD and DO students N = N/A Information collected and provided by each Rural Track program | Rural tracks (RT) commonly employ curriculum elements across all years of training. These elements serve to expose students to rural-related healthcare topics in years 1 and 2, provide early and lengthy rural clinical experience, and form a social network with other like-minded students and faculty. Clinical clerkships in rural communities take a variety of forms within each RT. Some students go for a year or more to a rural site that serves as a branch campus. More commonly, students spend several months in 1 rural location either rotating among physicians or with one main clinical faculty member or group. These longer experiences integrate the learning objectives of several formerly separate clerkship topics in a longitudinal model. | Post-only Rural: Defined by presence of Rural Track site | The 18 programs that have been able to track students' practice locations report that an average of 44% of their graduates practice in a rural area (range: 20-73%) | N/A | | Based on the findings and lessons learned in this report it would be helpful for RTs to track and report standardized parameters. This, in combination with knowledge of admissions and curriculum information, will help define and refine best practices for education of the future rural physician workforce.
Patterson, 2013^99^ | Multiple family medicine residencies with Rural Training Tracks supported by the RTT Technical Assistance Program Multiple Capacity: The 18 RTTs in this study each graduated an average of 1.5 physicians per year. | Family Medicine residents N = 123 Survey of RTT Programs, AMA Masterfile, American Board of Family Medicine, and Centers for Medicare and Medicaid Services. | The “1-2” family medicine rural training track (RTT) model combines 1 year of urban training with 2 years of rural training | Comparative study Rural: ZIP codes | 72% of graduates began clinical practice in rural areas (2-3× the proportion of family medicine residency graduates overall) | 3 years after graduation: some migration away from rural (60.6% of graduates in rural areas) | N/A | RTT programs continue to succeed in recruiting and preparing family physicians for practice with rural and underserved populations.
Phillips, 2009^60^ | US Allopathic Medical Schools US Capacity: N/A | Medical students N = 322,131 Medicare outpatient institutional claims filed from Rural Health Centers (RHC), and rural primary care hospitals. | Since 1976, DHHS Title VII funding has provided substantial support for Family Medicine educational programs at medical schools in many states. These curricula focus on development of primary care physicians who would care for urban and rural underserved populations | Post-only Rural: RUCA Code | Title VII-funded school experience increases likelihood of rural practice (OR 1.11, sign.) but not Title VII-funded residency (OR 0.90, sign.) Relative likelihood of association between Title VII funding and practice in rural area (RR 1.31, sign.) and practice in rural health center (RR 1.20, sign.). Practice in rural area associated with predoc Title VII training funding (RR 1.39, sign.) and matriculated in Title VII funded school (RR 1.31, sign.). | N/A | N/A | Title VII funding has languished over the last decade and is due for reauthorization. There is overwhelming evidence, confirmed in this study, of the beneficial effects associated with this small federal program.
Phillips, 2013^89^ | American Board of Family Medicine, Washington D.C. N/A Capacity: N/A | Residents who trained in Critical Access Hospital (CAH), RHC, or FQHC between 2001-2005 and compared to practice location in 2009 N = 3,430 Medicare claims 2001-2005, 2009, 2011 AMA Masterfile | RHC: nonurbanized area, MUA, HPSA, or GDSA, NPs, CNMs, or PAs at least 50% of the time the clinic is open, nonprofit or for profit, sliding fee schedule optional, provider productivity standard, cost-based Medicare, Medicaid prospective payment system. FQHC: MUA or MUP, tax-exempt nonprofit or public, Board of Directors, majority from community served, sliding fee schedule (must), provider productivity standard, FTCA malpractice coverage, Comprehensive Services requirement, cost-based Medicare, Medicaid, eligible for federal grant support. CAH: rural area, more than 35 miles from nearest hospital (15 in mountainous areas), 24-hour emergency care, 25 or fewer beds, average stay 96 hours or less, cost-based Medicare. [MUA: medically underserved area; GDSA: governor-designated shortage area; MUP: medically underserved population; FTCA: Federal Tort Claims Act] | Post-only Rural: N/A | 52.6% of the residents who trained in a CAH, 38.1% who trained in an RHC, and 31.2% who trained in an FQHC practiced in a safety net setting in 2009. Of CAH trainees, 40.9% remained in CAH, of RHC trainees, 10.4%, and, of FQHC trainees, 12.5% | N/A | N/A | Using Medicare claims data, the authors identified residents who trained in safety net settings and demonstrated that many went on to practice in these settings. They recommend that graduate medical education policy support or expand training in these settings to meet the surge in healthcare demand that will occur with the enactment of the Affordable Care Act insurance provision in 2014.
Rabinowitz, 2012^91^ | Jefferson Medical College; Pennsylvania Jefferson Medical College, Pennsylvania ; University of Minnesota-Duluth campus; University of Illinois Rockford campus Capacity: Jefferson PSAP average 12.1 grads per year; Duluth average 42.9 grads per year; RMED average 14.7 per year | Graduates of 3 rural-specific training programs N = 1,757 RP graduates versus 6,474 IMGs 2010 AMA Masterfile information on graduates from 3 rural programs and compared to practicing IMGs | 3 long-standing and successful rural programs (RPs) that include preferential admission of students likely to practice in rural areas as well as having a required rural curriculum: the Physician Shortage Area Program (PSAP) of Jefferson Medical College of Thomas Jefferson University; the University of Minnesota Medical School Duluth (UMD, a 2-year program where students take their final 2 years at the University of Minnesota Minneapolis); and the Rural Medical Education Program (RMED) at the University of Illinois College of Medicine at Rockford | Comparative study Rural: RUDT, practicing in a nonmetropolitan county according RUCC | 63% of graduates practicing in a rural area (IMGs: 26.5% were in rural areas) | N/A | Although there were almost 7× as many IMGs as RP graduates, the absolute number of RP graduates practicing rural family medicine was 1.5× greater than IMGs | Despite their relatively small size, RPs had a significant impact on rural family physician and primary care supply compared with the much larger cohort of IMGs. Wider adoption of the RP model would substantially increase access to care in rural areas compared with increasing reliance on IMGs or unfocused expansion of traditional medical schools.
Shipman, 2013^100^ | N/A N/A Capacity: N/A | US medical school graduates N = 1999-2001: 48,862, 2009-2011: 56,276 American Medical College Application Service for 2 time periods | Comparison of US medical school graduates prior to expansion (1999-2001) to a period 10 years after expansion (2009-2011); in 2006, AAMC had called for a 30% increase in MD-granting medical school enrollment by 2015 | Pre-post RUCC to classify the county as nonrural (codes 0-5) or rural (codes 6-9) | Schools with higher growth rates were more likely than schools with lower or no growth to produce graduates practicing in rural areas, range between 5.6 and 8.6% (p<.001) | N/A | Despite expansion, number of matriculants born in rural areas decreased | Despite expansion, the characteristics of matriculating medical students changed little, except at new schools. Further expansion may benefit from targeted consideration of workforce needs.
Talley, 2011^87^ | US Rural rotation site Capacity: N/A | Emergency medicine (EM) residents N = 197 residents completed a rural rotation 111/126 programs responded for 88% response rate | Comparison of different programs. Rural rotations as 1) required, 2) elective at predesignated site, 3) elective, but resident must create own rotation (no predesignated site), or 4) not available | Post-only Rural: N/A | 7% of residents who completed a rural rotation selected their initial job in a rural area. EM residency graduates were more likely to select a rural job when rural rotations were required (22%), compared to other options: predesignated (7%) or not predesignated (6%), elective or not available (7%; p < 0.001) | N/A | N/A | Elective rural rotations at predesignated sites increase resident exposure to rural areas compared to programs without, but neither was associated with rural practice after graduation. EM residency programs that required a rural rotation had increased resident selection of rural jobs, but only 5% of programs had this requirement.

AAFP = American Academy of Family Physicians, ACGME = Accreditation Council for Graduate Medical Education, min = minutes, FQHC = Federally Qualified Health Center, HPSA = Health Professional Shortage Areas, PY = program year, RHC = Rural Health Centers, RUCC = Rural-Urban Continuum Codes, RUDT = Rural-Urban Density Typology, RR = relative risk, OR = odds ratio

### Summary of Findings and Quality of Evidence for Key Question 5

This section summarizes the effectiveness of interventions aimed at healthcare providers in training with the goal of recruiting and retaining them in rural practice after graduation or completion of training. The primary outcome is recruitment success for rural healthcare.

The figure documents the percentage of students entering rural care across all studies reporting on 22 samples to provide a general overview.

Figure 2 Effect of Student Interventions on Recruitment to Rural Healthcare

Note: The histogram shows the relative frequency of reported recruitment success expressed as the percentage of trainees practicing in rural healthcare.

Across all identified approaches for healthcare providers in training, the percentage of choosing rural healthcare at least as the first site of practice varied widely. However, most estimates were in the range of 35 to 65%. The mean across all studies was 49%, the median 53%.

Restricting to the studies reporting on programs of a single institution, the mean recruitment success was 53% (median 55%). This included programs for medicine students as well as programs specifically aimed at residents in general surgery, psychiatry, and family medicine.

The 5 rural track programs exclusively aimed at medical residents^88,93,96,102,110^ reported a mean of providers successfully recruited into rural healthcare of 59% (median 60%). The largest success rate (86%) was reported for a small Texas rural training track program for family medicine residents, but the study included only 7 participants.^93^

Stratifying programs by intensity we found that training programs with greater than 6 months cumulative time spent in rural training had a median success rate of 51%, versus 53% for those comprising less than 6 months of rural experience.

Some of the identified studies reported on data across multiple training institutions. A study evaluating whether the 2006 AAMC request for a 30% increase in US MD-granting medical school enrollment by 2015 was successful in producing more physicians practicing in rural care showed that in schools with high growth, 8.6% of graduates practice in rural healthcare, compared to 5.6, 7.4, and 7.3% for no-, low-, and moderate-growth schools.^100^ A survey of program directors of emergency medicine residency programs reported that of all residents who had completed a rural rotation, 7% selected their initial job in a rural area.^87^ The percentage was 22% when restricting to students in programs where the rural rotation was a required element.

An evaluation of 35 medical schools with 18 rural track programs that were able to identify students' practice location reported an average of 44% of their graduates practice in rural areas (range 20-73%).^98^ A study accessing data from 3 rural programs that include preferential admission of students likely to practice in rural areas as well as having a required rural curriculum (Physician Shortage Area Program, Jefferson Medical College; University of Minnesota Medical School Duluth campus; and Rural Medical Education Program, University of Illinois) reported that 63% of the graduates practice in a rural area.^91^

A study found that of residents having trained in a critical access hospital, 48% practiced in a critical access hospital or a rural health clinic and 36% who trained in a rural health clinic practiced in a critical access hospital or a rural health clinic.^89^ Family medicine residencies with rural training tracks supported by the Rural Training Track Technical Assistance Program reported that 72% of graduates began clinical practice in rural areas.^99^

Among the studies that reported on retention of trainees in rural areas, between 37% and 82% of trainees stayed and practiced in the rural areas in which they were trained^105,110^ but data on duration of retention was lacking.

We did not identify any data specific to VA providers.