# REFERENCES

1 Rosenblatt RA, Chen FM, Lishner DM, Doescher MP. (2010). The Future of Family Medicine and Implications for Rural Primary Care Physician Supply. Final Report (#)125, August 2010.
2 Owen JA, Conaway MR, Bailey BA, Hayden GF. (2007). Predicting rural practice using different definitions to classify medical school applicants as having a rural upbringing. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
3 Ortiz J, Bushy A, Zhou Y, Zhang H. (2013). Accountable care organizations: benefits and barriers as perceived by Rural Health Clinic management. Rural and remote health.
4 Weeks WB, Wallace AE, West AN, Heady HR, Hawthorne K. (2008). Research on rural veterans: An analysis of the literature. Journal of Rural Health.
5 MacDowell M, Glasser M, Fitts M, Fratzke M, Peters K. (2009). Perspectives on rural health workforce issues: Illinois-Arkansas comparison. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
6 Doty B, Andres M, Zuckerman R, Borgstrom D. (2009). Use of Locum Tenens Surgeons to Provide Surgical Care in Small Rural Hospitals. World J.Surg.
7 Rosenblatt RA, Andrilla CH, Curtin T, Hart LG. (2006). Shortages of medical personnel at community health centers: implications for planned expansion. Jama.
8 Doty B, Zuckerman R, Finlayson S, Jenkins P, Rieb N, Heneghan S. (2008). General surgery at rural hospitals: a national survey of rural hospital administrators. Surgery.
9 MacDowell M, Glasser M, Fitts M, Nielsen K, Hunsaker M. (2010). A national view of rural health workforce issues in the USA. Rural and remote health.
10 Thompson MJ, Lynge DC, Larson EH, Tachawachira P, Hart LG. (2005). Characterizing the general surgery workforce in rural America. Archives of surgery (Chicago, Ill. : 1960).
11 Garrison-Jakel J. (2011). Patching the rural workforce pipeline--why don't we do more?. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
12 Mareck DG. (2011). Federal and state initiatives to recruit physicians to rural areas. The virtual mentor : VM.
13 Dill MJ, Salsberg ES. (2008). The Complexities of Physician Supply and Demand: Projections Through 2025. November 2008.
14 American Hospital Association. Physician Shortage &Distribution.
15 Cofer JB, Burns RP. (2008). The developing crisis in the national general surgery workforce. Journal of the American College of Surgeons.
16 US Department of Health and Human Services, Health Resources and Services Administration, National Center for Health Workforce Analysis. (2014). Technical Documentation for Health Resources Service Administration's Health Workforce Simulation Model.
17 Mullan F, Frehywot S, Jolley LJ. (2008). Aging, primary care, and self-sufficiency: health care workforce challenges ahead. The Journal of law, medicine & ethics : a journal of the American Society of Law, Medicine & Ethics.
18 Bridgham RG. (2009). Final report : HB 1615, (Chapter 367:3, Laws of 2008), establishing a Commission to Recommend Policies and Programs to Increase the Number of New Hampshire Individuals in Health Professions Servicing New Hampshire's Rural and Underserved Areas with a Focus on Primary Care.
19 Price J. (2010). The National Health Service Corps--a critical component of provider recruitment in North Carolina's rural and underserved communities. North Carolina medical journal.
20 Bowman RC. (2008). Measuring primary care: the standard primary care year. Rural Remote Health.
21 Hilty DM, Yellowlees PM, Cobb HC, Bourgeois JA, Neufeld JD, Nesbitt TS. (2006). Models of telepsychiatric consultation-liaison service to rural primary care. Psychosomatics.
22 Staton FS, Bhosle MJ, Camacho FT, Feldman SR, Balkrishnan R. (2007). How PAs improve access to care for the underserved. JAAPA : official journal of the American Academy of Physician Assistants.
23 Van Vleet A, Paradise J. (2015). Issue Brief: Tapping Nurse Practitioners to Meet Rising Demand for Primary Care.
24 Doescher MP, Andrilla CH, Skillman SM, Morgan P, Kaplan L. (2014). The contribution of physicians, physician assistants, and nurse practitioners toward rural primary care: findings from a 13-state survey. Medical care.
25 Lindsay S. (2007). Gender differences in rural and urban practice location among mid-level health care providers. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
26 Ricketts TC. (2005). Workforce issues in rural areas: A focus on policy equity. Am. J. Public Health.
27 Dolea C, Stormont L, Braichet JM. (2010). Evaluated strategies to increase attraction and retention of health workers in remote and rural areas. Bull World Health Organ.
28 Lehmann U, Dieleman M, Martineau T. (2008). Staffing remote rural areas in middle- and low-income countries: a literature review of attraction and retention. BMC health services research.
29 Deveney K, Hunter J. (2009). Education for rural surgical practice: the Oregon Health & Science University model. The Surgical clinics of North America.
30 Henry LR, Hooker RS, Yates KL. (2011). The role of physician assistants in rural health care: a systematic review of the literature. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
31 Baker E, Schmitz D, Epperly T, Nukui A, Miller CM. (2010). Rural Idaho Family Physicians' Scope of Practice. Journal of Rural Health.
32 Chipp C, Dewane S, Brems C, Johnson ME, Warner TD, Roberts LW. (2011). “If only someone had told me...”: lessons from rural providers. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
33 Filipova AA. (2014). Factors influencing the satisfaction of rural physician assistants: a cross-sectional study. Journal of allied health.
34 Huff C. (2014). Done recruiting? Start retaining. Trustee : the journal for hospital governing boards.
35 Meyer D. (2006). Technology, job satisfaction, and retention: rural mental health practitioners. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
36 Gagnon MP, Pollender H, Trepanier A, Duplaa E, Ly BA. (2011). Supporting health professionals through information and communication technologies: a systematic review of the effects of information and communication technologies on recruitment and retention. Telemedicine journal and e-health : the official journal of the American Telemedicine Association.
37 Palmer RT. (2014). Exploring online community among rural medical education students: A case study. Dissertation Abstracts International Section A: Humanities and Social Sciences.
38 Everitt-Deering P. (2008). The adoption of information and communication technologies by rural general practitioners a socio technical analysis.
39 Association of American Medical Colleges. (2006). AAMC Statement on the Physician Workforce, June 2006.
40 Myers MA, Reed KD. (2008). The virtual ICU (vICU): a new dimension for critical care nursing practice. Critical care nursing clinics of North America.
41 Pathman DE. (2006). What outcomes should we expect from programs that pay physicians'training expenses in exchange for service?. North Carolina medical journal.
42 Seligson RW, Highsmith PP. (2006). North Carolina Medical Society Foundation's Community Practitioner Program. North Carolina medical journal.
43 Chen C, Xierali I, Piwnica-Worms K, Phillips R. (2013). The redistribution of graduate medical education positions in 2005 failed to boost primary care or rural training. Health affairs (Project Hope).
44 Dorsey ER, Nicholson S, Frist WH. (2011). Commentary: improving the supply and distribution of primary care physicians. Academic medicine : journal of the Association of American Medical Colleges.
45 Viswanathan M, Ansari MT, Berkman ND, et al. (2008). Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions.
46 Swan N. (2007). Better access to mental health care. Education Lifeline to the Bush ;; no. 711; Variation: Education Lifeline to the Bush ;; no. 711.
47 Branch K. (2014). Alaska's Health Workforce Vacancy Study: 2012 Findings Report. August 2014.
48 Maizel SE. (2009). Maryland's surgical workforce-2007: an in-depth analysis and implications for the future. Journal of the American College of Surgeons.
49 Stewart RM, Liao LF, West M, Sirinek KR. (2013). The general surgery workforce shortage is worse when assessed at county level. Am. J. Surg.
50 Thomas KC, Ellis AR, Konrad TR, Holzer CE, Morrissey JP. (2009). County-level estimates of mental health professional shortage in the United States. Psychiatric services (Washington, D.C.).
51 Ghosh D, Sterns AA, Drew BL, Hamera E. (2011). Geospatial study of psychiatric mental health-advanced practice registered nurses (PMH-APRNs) in the United States. Psychiatric services (Washington, D.C.).
52 Rayburn WF, Klagholz JC, Murray-Krezan C, Dowell LE, Strunk AL. (2012). Distribution of American Congress of Obstetricians and Gynecologists Fellows and Junior Fellows in Practice in the United States. Obstet. Gynecol.
53 Williams TE, Satiani B, Ellison EC. (2011). A comparison of future recruitment needs in urban and rural hospitals: the rural imperative. Surgery.
54 Hendryx M. (2008). Mental health professional shortage areas in rural Appalachia. Journal of Rural Health.
55 Wilson EA, Whitler ET, Asher LM. (2011). Meeting the Need of a Rural State for Primary Care Physicians: A Health Care Reform Challenge. J. Public Health Manag. Pract.
56 Camargo CA, Ginde AA, Singer AH, et al. (2008). Assessment of emergency physician workforce needs in the United States, 2005. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine.
57 Chen F, Fordyce M, Andes S, Hart LG. (2010). Which medical schools produce rural physicians? A 15-year update. Academic medicine : journal of the Association of American Medical Colleges.
58 Fordyce MA, Doescher MP, Chen FM, Hart LG. (2012). Osteopathic physicians and international medical graduates in the rural primary care physician workforce. Family medicine.
59 Kornelsen J, Grzybowski S. (2005). Is local maternity care an optional service in rural communities?. Journal d'obstetrique et gynecologie du Canada : JOGC.
60 Phillips RL, Dodoo MS, Petterson S, et al. Specialty and geographic distribution of the physician workforce: what influences medical student & resident choices? March 2, 2009.
61 Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2012). The relationship between entering medical students' backgrounds and career plans and their rural practice outcomes three decades later. Academic medicine : journal of the Association of American Medical Colleges.
62 Renner DM, Westfall JM, Wilroy LA, Ginde AA. (2010). The influence of loan repayment on rural healthcare provider recruitment and retention in Colorado. Rural and remote health.
63 Mason PB, Cossman JS. (2012). Does one medical school's admission policy help a rural state “grow their own” physicians?. Journal of the Mississippi State Medical Association.
64 Smith B, Muma RD, Burks L, Lavoie MM. (2012). Factors that influence physician assistant choice of practice location. JAAPA : official journal of the American Academy of Physician Assistants.
65 Henry LR, Hooker RS. (2007). Retention of physician assistants in rural health clinics. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
66 US Department of Health and Human Services. (2006). Physician supply and demand: Projections to 2020.
67 Duffrin C, Diaz S, Cashion M, Watson R, Cummings D, Jackson N. (2014). Factors associated with placement of rural primary care physicians in North Carolina. Southern medical journal.
68 Glasser M, MacDowell M, Hunsaker M, et al. (2010). Factors and outcomes in primary care physician retention in rural areas.
69 Hancock C, Steinbach A, Nesbitt TS, Adler SR, Auerswald CL. (2009). Why doctors choose small towns: a developmental model of rural physician recruitment and retention. Social science & medicine (1982).
70 Helland LC, Westfall JM, Camargo CA, Rogers J, Ginde AA. (2010). Motivations and barriers for recruitment of new emergency medicine residency graduates to rural emergency departments. Annals of emergency medicine.
71 Heneghan SJ, Bordley Jt, Dietz PA, Gold MS, Jenkins PL, Zuckerman RJ. (2005). Comparison of urban and rural general surgeons: motivations for practice location, practice patterns, and education requirements. Journal of the American College of Surgeons.
72 Hughes S, Zweifler J, Schafer S, Smith MA, Athwal S, Blossom HJ. (2005). High school census tract information predicts practice in rural and minority communities. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
73 Jarman BT, Cogbill TH, Mathiason MA, et al. (2009). Factors correlated with surgery resident choice to practice general surgery in a rural area. Journal of surgical education.
74 Kimball EB, Crouse BJ. (2007). Perspectives of female physicians practicing in rural Wisconsin. WMJ : official publication of the State Medical Society of Wisconsin.
75 Pepper CM, Sandefer RH, Gray MJ. (2010). Recruiting and retaining physicians in very rural areas. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
76 Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2012). The relationship between matriculating medical students' planned specialties and eventual rural practice outcomes. Academic medicine : journal of the Association of American Medical Colleges.
77 Schiff T, Felsing-Watkins J, Small C, Takayesu A, Withy K. (2012). Addressing the physician shortage in Hawai'i: recruiting medical students who meet the needs of Hawai'i's rural communities. Hawai'i journal of medicine & public health : a journal of Asia Pacific Medicine & Public Health.
78 Shannon CK, Jackson J. (2011). A study of predictive validity of physician assistant students' reported practice site intent. The journal of physician assistant education : the official journal of the Physician Assistant Education Association.
79 Snyder J, Nehrenz G, Danielsen R, Pedersen D. (2014). Educational debt: does it have an influence on initial job location and specialty choice?. The journal of physician assistant education : the official journal of the Physician Assistant Education Association.
80 Stenger J, Cashman SB, Savageau JA. (2008). The primary care physician workforce in Massachusetts: implications for the workforce in rural, small town America. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
81 Whitacre BE, Pace V, Hackler JB, Janey M, Landgraf CE, Pettit WJ. (2011). An evaluation of osteopathic school programs designed to promote rural location by graduates. International Journal of Osteopathic Medicine.
82 Zink T, Center B, Finstad D, et al. (2010). Efforts to graduate more primary care physicians and physicians who will practice in rural areas: examining outcomes from the university of Minnesota-duluth and the rural physician associate program. Academic medicine : journal of the Association of American Medical Colleges.
83 Kahn TR, Hagopian A, Johnson K. (2010). Retention of J-1 visa waiver program physicians in Washington State's health professional shortage areas. Academic medicine : journal of the Association of American Medical Colleges.
84 Wheeler DL, L CE. (2009). Oklahoma State University Center for Rural Health report to the Senate interim study on comprehensive assessment of healthcare workforce issues.
85 (2007). Bringing health care to the heartland : an evaluation of Minnesota's loan forgiveness programs for select health care occupations.
86 Wheeler M, Endres M, Pauley K, Mahone M, Melton N. (2013). Dr. Who? Providing stability to recruiting and retaining health care professionals in West Virginia. The West Virginia medical journal.
87 Talley BE, Ann Moore S, Camargo CA, Rogers J, Ginde AA. (2011). Availability and potential effect of rural rotations in emergency medicine residency programs. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine.
88 Bonham C, Salvador M, Altschul D, Silverblatt H. (2014). Training Psychiatrists for Rural Practice: A 20-Year Follow-up. Academic Psychiatry.
89 Phillips RL, Petterson S, Bazemore A. (2013). Do residents who train in safety net settings return for practice?. Academic medicine : journal of the Association of American Medical Colleges.
90 Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2011). Increasing the supply of rural family physicians: recent outcomes from Jefferson Medical College's Physician Shortage Area Program (PSAP). Academic medicine : journal of the Association of American Medical Colleges.
91 Rabinowitz HK, Petterson S, Boulger JG, et al. (2012). Medical school rural programs: a comparison with international medical graduates in addressing state-level rural family physician and primary care supply. Academic medicine : journal of the Association of American Medical Colleges.
92 Quinn KJ, Kane KY, Stevermer JJ, et al. (2011). Influencing residency choice and practice location through a longitudinal rural pipeline program. Academic medicine : journal of the Association of American Medical Colleges.
93 Nash LR, Olson MM, Caskey JW, Thompson BL. (2008). Outcomes of a Texas family medicine residency rural training track: 2000 through 2007. Texas medicine.
94 Halaas GW, Zink T, Finstad D, Bolin K, Center B. (2008). Recruitment and retention of rural physicians: outcomes from the rural physician associate program of Minnesota. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
95 Halaas GW. (2005). The Rural Physician Associate Program: successful outcomes in primary care and rural practice. Rural and remote health.
96 Antonenko DR. (2009). Rural surgery: the North Dakota experience. The Surgical clinics of North America.
97 Deveney K, Deatherage M, Oehling D, Hunter J. (2013). Association between dedicated rural training year and the likelihood of becoming a general surgeon in a small town. JAMA surgery.
98 Deutchman M. (2013). Medical School Rural Tracks in the US Policy brief: September 2013.
99 Patterson DG, Longenecker R, Schmitz D, Phillips RL, Skillman SM, Doescher MP. (2013). January 2013 Policy Brief: Rural Residency Training for Family Medicine Physicians: Graduate Early-Career Outcomes, 2008-2012.
100 Shipman SA, Jones KC, Erikson CE, Sandberg SF. (2013). Exploring the workforce implications of a decade of medical school expansion: variations in medical school growth and changes in student characteristics and career plans. Academic medicine : journal of the Association of American Medical Colleges.
101 Baker HH, Pathman DE, Nemitz JW, Boisvert CS, Schwartz RJ, Ridpath LC. (2012). Which U.S. medical schools are providing the most physicians for the Appalachian region of the United States?. Academic medicine : journal of the Association of American Medical Colleges.
102 Crane S, Jones G. (2014). Innovation in rural family medicine training: the Mountain Area Health Education Center's rural-track residency program. North Carolina medical journal.
103 Crump WJ, Fricker RS, Ziegler C, Wiegman DL, Rowland ML. (2013). Rural track training based at a small regional campus: equivalency of training, residency choice, and practice location of graduates. Academic medicine : journal of the Association of American Medical Colleges.
104 Glasser M, Hunsaker M, Sweet K, MacDowell M, Meurer M. (2008). A comprehensive medical education program response to rural primary care needs. Academic medicine : journal of the Association of American Medical Colleges.
105 MacDowell M, Glasser M, Hunsaker M. (2013). A decade of rural physician workforce outcomes for the Rockford Rural Medical Education (RMED) Program, University of Illinois. Academic medicine : journal of the Association of American Medical Colleges.
106 Kallail KJ, McCurdy S. (2010). Scholars in Rural Health: Outcomes From an Assured Admissions Program. Fam. Med.
107 Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2011). Increasing the supply of women physicians in rural areas: outcomes of a medical school rural program. Journal of the American Board of Family Medicine : JABFM.
108 Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2013). Retention of rural family physicians after 20-25 years: outcomes of a comprehensive medical school rural program. Journal of the American Board of Family Medicine : JABFM.
109 Rabinowitz HK, Diamond JJ, Markham FW, Rabinowitz C. (2005). Long-term retention of graduates from a program to increase the supply of rural family physicians. Academic medicine : journal of the Association of American Medical Colleges.
110 Ross R. (2013). Fifteen-year outcomes of a rural residency: aligning policy with national needs. Family medicine.
111 Vogt HB. (2008). South Dakota's rural physician shortage: how might it be addressed?. South Dakota medicine : the journal of the South Dakota State Medical Association.
112 (2008). Shortage of general surgeons coming?. OR Manager.
113 Whitcomb ME. (2005). The challenge of providing doctors for rural America. Academic medicine : journal of the Association of American Medical Colleges.
114 Philipp DL, Wright DL. (2005). Recruiting healthcare professionals to rural areas. Radiology management.
115 Thomas CR, Holzer CE. (2006). The continuing shortage of child and adolescent psychiatrists. Journal of the American Academy of Child and Adolescent Psychiatry.
116 Fraher EP, Knapton A, Sheldon GF, Meyer A, Ricketts TC. (2013). Projecting surgeon supply using a dynamic model. Annals of surgery.
117 Gunn J. (2013). Minnesota's rural health workforce shortages. Minnesota medicine.
118 Weldon T. (2008). Physician shortages and the medically underserved. Trends in America; Variation: Trends in America.
119 US Department of Health and Human Services, Health Resources and Services Administration. (2015). Lists of Designated Primary Medical Care, Mental Health, and Dental Health Professional Shortage Areas. Federal register.
120 Wade ME, Brokaw JJ, Zollinger TW, et al. (2007). Influence of hometown on family physicians' choice to practice in rural settings. Family medicine.
121 Grobler L, Marais BJ, Mabunda SA, Marindi PN, Reuter H, Volmink J. (2009). Interventions for increasing the proportion of health professionals practising in rural and other underserved areas. The Cochrane database of systematic reviews.
122 Crouse BJ, Munson RL. (2006). The effect of the physician J-1 visa waiver on rural Wisconsin. WMJ : official publication of the State Medical Society of Wisconsin.
123 Wilson NW, Couper ID, De Vries E, Reid S, Fish T, Marais BJ. (2009). A critical review of interventions to redress the inequitable distribution of healthcare professionals to rural and remote areas. Rural and remote health.
124 Lee DM, Nichols T. (2014). Physician recruitment and retention in rural and underserved areas. International journal of health care quality assurance.
125 Mbemba G, Gagnon MP, Pare G, Cote J. (2013). Interventions for supporting nurse retention in rural and remote areas: an umbrella review. Human resources for health.
126 Buykx P, Humphreys J, Wakerman J, Pashen D. (2010). Systematic review of effective retention incentives for health workers in rural and remote areas: towards evidence-based policy. The Australian journal of rural health.
127 Rabinowitz HK, Diamond JJ, Markham FW, Wortman JR. (2008). Medical school programs to increase the rural physician supply: a systematic review and projected impact of widespread replication. Academic medicine : journal of the Association of American Medical Colleges.
128 US Department of Health and Human Services. (2013). The Affordable Care Act- What it Means for Rural America.
129 Patterson DG, Keppel G, Skillman SM, Berry C, Daniel C, Doescher MP. (2015). Recruitment of Non-U.S. Citizen Physicians to Rural and Underserved Areas through Conrad State 30 J-1 Visa Waiver Programs. Final Report #148, April 2015.
130 Wendling AL, Phillips J, Short W, Fahey C, Mavis B. (2015). Thirty Years Training Rural Physicians: Outcomes From the Michigan State University College of Human Medicine Rural Physician Program. practice.
131 US Department of Health and Human Services, Health Resources and Services Administration. U.S. Health Workforce Projections.
132 Peterson LE, Bazemore A, Bragg EJ, Xierali I, Warshaw GA. (2011). Rural-urban distribution of the U.S. Geriatrics physician workforce. Journal of the American Geriatrics Society.
133 Lynge DC, Larson EH, Thompson M, Rosenblatt RA, Hart LG. (2008). A longitudinal analysis of the general surgery workforce in the United States, 1981-2005. Arch. Surg.
134 Toner JA, Ferguson KD, Sokal RD. (2009). Continuing interprofessional education in geriatrics and gerontology in medically underserved areas. Journal of Continuing Education in the Health Professions.
135 Suter E, Deutschlander S, Mickelson G, et al. (2012). Can interprofessional collaboration provide health human resources solutions? A knowledge synthesis. Journal of interprofessional care.
136 Tumosa N, Horvath KJ, Huh T, et al. (2012). Health care workforce development in rural america: when geriatrics expertise is 100 miles away. Gerontology & geriatrics education.
137 Holmes GM. (2005). Increasing physician supply in medically underserved areas. Labour Econ.
138 Pathman DE, Fryer GE, Phillips RL, Smucny J, Miyoshi T, Green LA. (2006). National Health Service Corps staffing and the growth of the local rural non-NHSC primary care physician workforce. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
139 Alfero C. (2014). FORWARD NM Pathways to Health Careers.
140 Primm D. (2014). Tennessee Rural Partnership.
141 Stempniak M. (2012). The hiring headache. Rural hospitals band together to lure physicians. Hospitals & health networks / AHA.
142 Schmitz DF, Baker E, Nukui A, Epperly T. (2011). Idaho rural family physician workforce study: the Community Apgar Questionnaire. Rural and remote health.