# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by the Office of Rural Health (ORH), for an evidence review examining the literature describing access needs and limitations for Veterans in rural settings and the interventions that have been shown to improve the recruitment and retention of healthcare providers in rural settings. Key questions were developed with input from the topic nominator, the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

The Key Questions were:

1. What are the current versus projected healthcare provider needs by numbers and disciplines in the next 20 years in rural areas?
2. What factors influence healthcare providers' geographic choices for practice?
3. What interventions have been shown to increase rural healthcare provider recruitment?
4. What interventions have been shown to increase rural healthcare provider retention?
5. What is the efficacy of current rural specific resident and healthcare profession student training and education efforts?

The review was registered in PROSPERO: CRD42015025403.

## SEARCH STRATEGY

We searched the electronic databases PubMed, CIN/AHL, Web of Science, SCOPUS, PsycINFO, ERIC, WorldCat, and Grey Literature Report for English-language research published in the last 10 years (2005-2015). In addition, we reference-mined pertinent reviews, accessed targeted online resources including www.raconline.org, http://bhpr.hrsa.gov/healthworkforce, and www.ruralhealthresearch.org, and consulted with topic experts to identify pertinent US studies.

## STUDY SELECTION

Two independent reviewers screened the titles and abstracts of retrieved citations. Citations deemed relevant by at least one reviewer were obtained as full text. Full-text publications were screened against prespecified eligibility criteria. Any disagreements were resolved by consensus decision after discussion by all investigators.

To be included in the systematic review, studies had to meet the following criteria, organized in the PICOTS framework:

KQ1 PICOTS: What are the current versus projected healthcare provider needs by numbers and disciplines in the next 20 years in rural areas?

- Population(s): Studies on healthcare providers relevant to rural Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals (family medicine, internal medicine, emergency medicine, and obstetrics/gynecology physicians; general surgeons; pediatricians; geriatricians; psychiatrists; nurse practitioners; and physician assistants) were eligible for inclusion. In addition, studies using patient demographics relevant to adults to determine objective healthcare provider needs were eligible to provide data. Studies exclusively providing data for other professions and specialties were not eligible.
- Intervention(s): n/a
- Comparator / Study design: Studies eligible to demonstrate the current healthcare needs required a comparator (eg, rural vs urban settings). Studies eligible to predict future provider needs required the use of statistical modeling techniques; vague estimates (eg, “need is likely to increase”) were not eligible.
- Outcome(s): Studies reporting on current and projected healthcare provider needs in rural areas were eligible. Studies only reporting on provider supply without needs or demand assessment were excluded. We accepted the author's definition of need, demand, shortage, or benchmarks (eg, existing guidelines for patient-provider ratio), and patient healthcare access measures (eg, projected number of required physicians to maintain patient-provider ratio). Studies addressing demand without specific numbers for the healthcare provider groups of interest and studies not providing data specifically to rural areas were not eligible.
- Timing: Studies reporting on provider need since 2005 regardless of the start of the evaluation period, and studies making predictions beyond 2015 were eligible.
- Setting: Studies had to report on US rural healthcare practice settings, using the authors' definition (remote, not urban, non-metropolitan), to be eligible.

KQ2 PICOTS: What factors influence healthcare providers' geographic choices for practice?

- Population(s): Studies in healthcare providers relevant to rural Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals (family medicine, internal medicine, emergency medicine, and obstetrics/gynecology physicians; general surgeons; pediatricians; geriatricians; psychiatrists; nurse practitioners; and physician assistants) were eligible for inclusion. Studies exclusively providing data for other professions and specialties were not eligible. Studies presenting analytic data predicting healthcare providers' choices for practice were included but studies exclusively reporting data from other participant groups (eg, hospital administrators) reporting on perceived healthcare providers' choices were not eligible.
- Intervention(s) / Independent variables: Studies of provider-reported or other analytically derived factors potentially associated with geographic choices for practicing in rural care were eligible. Analytically derived factors were limited to variables preceding practicing in rural care such as demographic or provider training characteristics (eg, gender, growing up in rural community, rural track training). Studies exclusively associating training programs with practicing in rural healthcare were documented in KQ5.
- Comparator / Study design: Surveys and interviews with healthcare providers as well as analytic studies identifying predictors of practice in rural settings published in journal articles or reports were eligible for inclusion. Studies only in abbreviated or other formats (eg, conference abstracts dissertations) were excluded.
- Outcome(s): Studies reporting associations and predictions for practicing in rural care were eligible. Studies only assessing factors associated with the intent of practicing in rural care and case studies reporting experiences of a single provider were not eligible.
- Timing: Studies reporting on practicing in rural care since 2005 were eligible regardless of the timing of the predictor variables (eg, growing up in a rural area), start of the evaluation period, exposure duration, or length of follow-up.
- Setting: Studies had to report on US rural (as defined by the author) healthcare practice settings to be eligible. Studies predicting practicing in rural versus very remote US areas were eligible but studies comparing choices between US and international settings were excluded.

KQ3 PICOTS: What interventions have been shown to increase rural healthcare provider recruitment?

- Population(s): Studies in healthcare providers relevant to rural Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals (family medicine, internal medicine, emergency medicine, and obstetrics/gynecology physicians; general surgeons; pediatricians; geriatricians; psychiatrists; nurse practitioners; and physician assistants) were eligible for inclusion in the review. Studies exclusively providing data for other professions and specialties were not eligible. Interventions targeting providers in training were eligible for KQ5.
- Intervention(s): Interventions aiming to increase provider recruitment and studies addressing recruitment regardless of the aim of the provider intervention were eligible (eg, financial incentives, visa programs, educational interventions, improving the practice environment initiatives).
- Comparator / Study design: Studies with concurrent (eg, randomized controlled trials [RCT]) or historic (eg, pre-post) comparators were eligible, and post-only studies were eligible when they reported on a distinct cohort of participants.
- Outcome(s): Studies reporting on recruitment success measures and studies reporting on retention measures, such as extended practice in rural areas after a mandatory period of time required by the intervention, were eligible. Post-only studies were eligible only if they reported numerical recruitment or retention data together with a denominator (eg, number of participants in study group); publications making general statements such as “program was successful” were excluded.
- Timing: Studies reporting data on practicing in rural care since 2005 were eligible regardless of the timing of the intervention, start of the evaluation period, intervention duration, or length of follow-up.
- Setting: Studies had to report on US rural (as defined by the author) healthcare practice settings to be eligible.

KQ4 PICOTS: What interventions have been shown to increase rural healthcare provider retention?

- Population(s): Studies in healthcare providers relevant to rural Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals (family medicine, internal medicine, emergency medicine, and obstetrics/gynecology physicians; general surgeons; pediatricians; geriatricians; psychiatrists; nurse practitioners; and physician assistants) were eligible for inclusion. Studies exclusively providing data for other professions and specialties were not eligible.
- Intervention(s): Interventions aiming to increase provider recruitment and retention, and studies addressing recruitment and retention regardless of the aim of the provider intervention were eligible.
- Comparator / Study design: Studies with concurrent (eg, RCT) or historic (eg, pre-post) comparators were eligible. Post-only studies were only included if they reported on a distinct cohort of participants.
- Outcome(s): Studies reporting on provider retention measures (eg, staff turnover, employment duration, provider loss rate, moving to rural area) were eligible. Post-only studies were only included if they reported numerical recruitment or retention data together with a denominator (eg, number of participants in study group); publications making general statements such as “program was successful” were excluded.
- Timing: Studies reporting data on practicing in rural care since 2005 were eligible regardless of the timing of the intervention, start of the evaluation period, intervention duration, or length of follow-up.
- Setting: Studies had to report on US rural (as defined by the author) healthcare practice settings to be eligible.

KQ5 PICOTS: What is the efficacy of current rural-specific resident and healthcare profession student training and education efforts?

- Population(s): Studies in healthcare providers in training relevant to rural Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals (family medicine, internal medicine, emergency medicine, and obstetrics/gynecology physicians; general surgeons; pediatricians; geriatricians; psychiatrists; nurse practitioners; and physician assistants) were eligible for inclusion. Studies exclusively providing data for students of other professions and specialties were not eligible.
- Intervention(s): Training and educational programs specific to rural healthcare and programs explicitly aiming to increase provider recruitment for rural areas were eligible.
- Comparator / Study design: Studies published in peer-reviewed journal articles were eligible regardless of the presence or the type of comparator. Studies not peer-reviewed or documented only in abbreviated form (eg, dissertations, conference abstracts were excluded).
- Outcome(s): Studies reporting on recruitment success measures were eligible. Studies only reporting on the intention to practice in rural healthcare or other effectiveness measures of programs and intervention-specific outcomes were excluded.
- Timing: Studies reporting data on practicing in rural care since 2005 were eligible regardless of the timing of the intervention, start of the evaluation period, intervention duration, or length of follow-up.
- Setting: Studies reporting on US training sites and reporting on US rural healthcare practice settings (as defined by the author) were eligible. Training sites were defined as formally recognized and accredited locations for healthcare student and resident clinical education.

Publications reporting on the same dataset were abstracted as one study.

## DATA ABSTRACTION

For KQ1 studies (current and future provider need), we abstracted the geographic region the study aimed to cover, the targeted provider groups, the predictive timeframe category (current vs future demand) and the specified timeframe the study addressed, the data source, the definition of “rural” or other relevant case definition variables, the analytic method, the results for rural healthcare, and the authors' conclusion.

The evidence table for KQ2 studies (provider choices to practice in rural healthcare) documents the geographic region, the provider groups covered, the number of participants together with the response rate of all invited and eligible participants, the study design and comparators (where applicable), the results associated with predictions based on participant characteristics, results with regard to rural healthcare setting characteristics, predictive results regarding financial aspects, results for other potential predictors, and the authors' conclusions.

Studies reporting on interventions relevant to KQ3 (provider recruitment interventions) or KQ4 (provider retention interventions) documented the geographic regions included in the study, the targeted provider groups, the number of participants, the study design and the comparator (concurrent or historic), results regarding recruitment success, results regarding retention, and the authors' conclusion.

The evidence table for KQ5 (programs for healthcare providers in training) studies documents the geographic region of the school and the training / rural placement location, the discipline of the targeted providers in training, the number of trainees evaluated in the research study, the content of the training including duration of rural placement (where applicable), the capacity of the school, the study design (post-only, pre-post, comparative study with concurrent comparator, and random participant assignment), source of outcome data, definition of “rural,” rural healthcare recruitment results, information on retention in rural healthcare, other notable outcomes, and the authors' conclusion.

## QUALITY ASSESSMENT

Due to the diversity of included studies, the quality assessment primarily targeted study design-associated characteristics and inherent limitations in addition to key risk of bias dimensions appropriate for the type of question the study aimed to answer.^45^

For KQ1, the quality assessment concentrated on the data source reporting (detection bias) and whether predictions exceeded the sample (external validity).

For KQ2, the quality assessment targeted the risk of bias due to response rate limitations (selection bias) and confounding variables (detection bias).

For KQ3 and KQ4 (provider intervention studies), the quality assessment considered selection, performance, attrition, detection, reporting, and other key sources of bias. Selection bias assessed whether the study was based on a highly selective and not representative sample of the target population (eg, depending on survey respondents). Performance bias assessed whether fidelity to the intervention protocol was maintained. Attrition bias assessed the loss to follow-up. Detection bias evaluated whether the data were based on a reliable source. Reporting bias assessed whether key outcomes were apparently missing from the analysis and results were based on surrogate measures of recruitment success (eg, number of offers made, not number of successfully recruited providers). The other source of bias category determined whether the study reported on a related concept rather than rural healthcare (eg, practicing in very rural areas).

For KQ5, the quality assessment focused on the completeness of follow-up (attrition bias).

## DATA SYNTHESIS

The identified research is presented in a narrative synthesis for each of the 5 key questions. Evidence tables summarize each study meeting inclusion criteria.

Some publications were relevant to more than one key question, such as studies evaluating the success of a recruitment intervention and analyzing predictors of practicing in rural healthcare within intervention groups. All studies investigating geographic choices of practitioners were extracted for KQ2, regardless of whether the study also contributed to other evidence tables. Given the conceptual overlap, studies addressing programs aimed at students as well as practitioners were abstracted for KQ3 and KQ4 (provider recruitment and retention). Given the conceptual overlap, studies reporting on recruitment and retention measures were abstracted for KQ3 and discussed in the KQ4 section. KQ4 was reserved for studies that evaluated interventions that exclusively focused on the retention of practicing healthcare professionals. Studies evaluating programs exclusively aimed at students or residents, and not fully trained healthcare providers, were summarized in the KQ5 section.

## RATING THE BODY OF EVIDENCE

Where possible a summary of findings and quality of evidence table was used to summarize the existing evidence. Based on the GRADE working group,^46^ the quality of the evidence was categorized as follows:

High: We are very confident that the true effect lies close to that of the estimate of the effect.

Moderate: We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.

Low: Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.

Very low: We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect.

GRADE evaluates the quality of the evidence across all identified studies contributing to the outcome of interest. We took the standard criteria Study limitation and risk of bias, Inconsistency, Indirectness, Imprecision, Publication bias, Large effect, and Dose response, and All plausible residual confounding would reduce a demonstrated effect and/or would suggest a spurious effect if no effect was observed into account when grading the evidence. The starting point for all key questions was moderate evidence (not high evidence) because the data were not based on RCTs or equivalently strong research design studies. Risk of bias, Inconsistency, Indirectness, Imprecision, and Publication bias can lower the quality, Large effect, Dose response, and All plausible residual confounding can upgrade the quality of the body of evidence (where applicable). Neither of the key questions could be answered by a standard intervention study such as an RCT, hence the grading rested primarily on study limitation, risk of bias, and inconsistency across studies assessing the same factor.

## TECHNICAL EXPERT PANEL

The TEP guiding the project included: Nancy Maher, PhD, Program Analyst, Office of Rural Health, VHA Office of Rural Health; Stephanie Kondrick, VHA National Workforce Planner, Healthcare Talent Management Office; Ray Lash, MD, Director, ORH Rural Health Training Initiative, VA Maine Healthcare System; Dan Mareck, MD, Chief Medical Officer, Federal Office of Rural Health Policy/HRSA; George Zangaro, PhD, RN, Director, National Center for Health Workforce Analysis, HHS Bureau of Health Workforce; Randy Longenecker, MD, Assistant Dean, Rural and Underserved Programs and Professor of Family Medicine, Ohio University; Judy Howe, PhD, Director, ORH Rural Health Training Initiative, Bronx VAMC; Peter Kaboli, MD, Director of the Veterans Rural Health Resource Center — Central Region, Associate Professor at the University of Iowa Carver College of Medicine, Iowa City VA Medical Center; Thomas Klobucar, PhD, Deputy Director, Office of Rural Health, VHA Office of Rural Health (10P1R); and Janice Garland, MPH, Health Systems Specialist, Office of Rural Health, VHA Office of Rural Health (10P1R).

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our responses are documented in Appendix 4.