# INTRODUCTION

Approximately 20 percent of the US total population lives in rural areas;^1^ exact estimates vary depending on the specific definition of rural.^2^ Compared to their urban counterparts, rural communities tend to have older residents and report higher rates of chronic diseases.^3^ In order to obtain healthcare services, members of these geographically dispersed rural populations must often travel great distances and incur significant costs.^4^ Rural Veterans represent a third of the total VA enrolled population.

Surveys indicate that rural communities struggle with recruiting as well as retaining healthcare providers and experience a healthcare provider shortage with ongoing, long-term vacancies.^5-9^ Estimates differ by provider group but, for example, less than 12 percent of US physicians practice in rural areas.^1^ Hence one fifth of the nation's population resides outside metropolitan areas, but only about a tenth of the nation's physicians are to be found there. Prior publications have frequently concluded that the shortage will increase over time and that shortages of specific provider groups are more pronounced in rural areas compared to their urban counterparts.^10-14^

In order to ensure access to rural healthcare services, it is essential to reliably determine and quantify the current demand and shortage of healthcare providers. Furthermore, given the many years of training required for key healthcare personnel such as physicians, predictive studies are crucial to anticipate future provider workforce needs. Professional bodies, including state and national agencies, may then use study results and take adequate steps to ensure healthcare delivery in rural communities. Prediction models need to take a variety of variables into account, including current workforce status and anticipated workforce,^15,16^ an aging population,^17^ changes in patient case mix, federal and state programs that address already perceived shortages,^4,12,18,19^ and changes in models of care with implications for demand of individual provider groups.^20-24^

In recent years, more research has concentrated on exploring determinants of geographic practice choices of healthcare providers. Insight into the relative importance of demographic characteristics and motivational factors may provide indications which groups of providers should be targeted to maximize return on recruitment efforts.^25^ Systematically exploring the strength of associations may also contribute to selecting strategies that address demand, such as those that seem predominately normative (ie, matching inclinations and background of candidates), coercive (eg, a mandatory period of practice in rural healthcare), or utilitarian (eg, continuous education programs to support practitioners in rural healthcare) policy approaches.^26^

Many approaches have been suggested and resources spent aiming to increase the number of providers practicing in rural healthcare. The international literature has pointed out emerging evidence,^27,28^ but it is not clear whether interventions can be applied to the unique US healthcare system and infrastructure. Our knowledge about which recruitment strategies are evidence-based and have indeed been shown to be successful and cost-effective in recruiting healthcare providers is limited. Furthermore, evaluating the effects of federal, state, or local programs is a complex undertaking and the relative importance and success rate of programs has to be evaluated within the context of the current healthcare system.

Rural providers commonly treat a great diversity of conditions and perform a wide variety of procedures, often without specialized training and with limited access to professional support such as colleagues and educational opportunities.^29-31^ In addition, the intersection of rural living and healthcare challenges may create additional barriers to care that providers are not trained to navigate, as for example shown in the following quote: “I think when you work in a rural setting you can find yourself on call 24 hours a day. People will come to you in ways that are unseeing, unbelievably naive or intrusive, or completely innocent, almost with the expectation that you can do much more than you can.”^32^ It is crucial that healthcare provider organizations support providers and identify appropriate efforts that ensure workplace retention of recruited providers.^33,34^ However, evidence syntheses on the effectiveness and comparative effectiveness of interventions aiming to increase healthcare provider retention are sparse and frequently outdated, as the care environment has changed in the last decade through the increased use of internet applications and advanced communication technologies.^35-38^ Telehealth and access to specialist input through online, real time exchanges, and easy access to high-quality videoconferencing technology can now support providers in remote locations. However, whether these innovations are successful in increasing retention of healthcare providers is an open question.

Finding ways to get physicians to practice in underserved areas has been an ongoing priority for organizations such as the Association of American Medical Colleges (AAMC). In 2006, AAMC called for a 30 percent increase in MD-granting medical school enrollment by 2015.^39^ A systematic review with literature searches to 2006 highlighted efforts to target healthcare providers in training, for example by adding rural tracks to medical schools.^40^ Since the review, a substantial amount of new research has been published and results of implemented programs and reforms to address shortcomings^41-44^ should also have become apparent.

The complexity of rural healthcare provision requires careful and systematic evaluation of individual contributing factors. The purpose of this systematic review is to examine the research describing healthcare provider need, exploring geographic provider choices, synthesizing evidence on interventions to increase provider recruitment and provider retention, and documenting the efficacy of student and resident training for rural healthcare in the US in the last decade. The review concentrates on key healthcare provider groups with long training periods, requiring workforce planning ahead of time, and that are critical to rural Community-Based Outpatient Clinics, Rural Health Clinics, and Critical Access Hospitals. The review does not provide a historic overview but concentrates on research that addresses the review questions in a contemporary context, applicable to the current healthcare environment. We did not restrict to a particular definition of “rural” but limited to US studies to maximize relevance and applicability to the VA. The review aims to systematically document current published, empirical evidence reporting on the outcomes of interest for rural healthcare.