# APPENDIX 3 RISK OF BIAS ASSESSMENT

KQ1 STUDIES

ID | Data source reporting | External validity
Branch, 2014^47^ | Low risk | Low risk
Camargo, 2008^56^ | Low risk | Low risk
Ghosh, 2011^51^ | Low risk | Low risk
Hendryx, 2008^54^ | Low risk | Low risk
Maizel, 2009^48^ | Low risk | Unclear
Rayburn, 2012^52^ | Low risk | Unclear
Rosenblatt, 2010^1^ | Low risk | Low risk
Stewart, 2013^49^ | Low risk | Low risk
Thomas, 2009^50^ | Low risk | Unclear
Williams, 2011^53^ | Low risk | Low risk
Wilson, 2011^55^ | Low risk | Low risk

KQ2 STUDIES

ID | Response rate | Confounding variables | Other limitations
Chen, 2010^57^ | Unclear | High risk
DHHS, 2006^66^ | Unclear | High risk
Duffrin, 2014^67^ | High risk | High risk
Fordyce, 2012^58^ | Unclear | High risk
Glasser, 2010^68^ | Low risk | High risk
Hancock, 2009^69^ | High risk | High risk | Recall bias and small sample size with likely selection bias
Helland, 2010^70^ | Low risk | High risk
Heneghan, 2005^71^ | High risk | High risk | Selection bias, response bias, did not address non-responders
Henry, 2007^65^ | High risk | High risk | Qualitative results only
Hughes, 2005^72^ | Unclear | High risk
Jarman, 2009^73^ | High risk | High risk
Kimball, 2007^74^ | Low risk | High risk | Qualitative study with selection bias
MacDowell, 2013^105^ | Unclear | High risk
Mason, 2012^63^ | Unclear | Unclear
Pepper, 2010^75^ | Low risk | High risk
Phillips,2009^60^ | Unclear | Low risk
Phillips, 2013^89^ | Low risk | High risk
Rabinowitz, 2012^61^ | Low risk | High risk
Renner, 2010^62^ | Low risk | Unclear
Schiff, 2012^77^ | Low risk | High risk
Shannon, 2011^78^ | Unclear | Low risk | Use of self-reported data, limited sample size, and limited external validity
Smith, 2012^64^ | High risk | High risk
Snyder, 2014^79^ | High risk | High risk
Stenger, 2008^80^ | Low risk | Unclear | Self-reported data, selection bias
Whitacre, 2010^81^ | Unclear | Low risk
Zink, 2010^82^ | Unclear | Unclear

KQ3 AND KQ4 STUDIES

ID | Selection bias | Performance bias | Attrition bias | Detection bias | Other bias
Kahn, 2010^83^ | High risk | Low risk | Low risk | Low risk | N/A
No Author, 2007^85^ | High risk | Low risk | Low risk | Low risk | N/A
Renner, 2010^62^ | High risk | Unclear | Low risk | Low risk | N/A
Wheeler, 2009^84^ | High risk | Low risk | Low risk | Low risk | N/A
Wheeler, 2013^86^ | High risk | Unclear | Unclear | Unclear | Recruitment data no denominator, retention data not stratified by program

KQ5 STUDIES

ID | Selection bias
Antonenko, 2009^96^ | High risk
Baker, 2012^101^ | Unclear
Bonham, 2014^88^ | High risk
Crane, 2014^102^ | High risk
Crump, 2013^103^ | Unclear
Deutchman, 2013^98^ | High risk
Deveney, 2009^29,97^ | High risk
Glasser, 2008^68,104^ | High risk
Kallail, 2010^106^ | High risk
Mason, 2012^63^ | High risk
Nash, 2008^93^ | High risk
Patterson, 2013^99^ | Unclear
Phillips,2009^60^ | Low risk
Phillips, 2013^89^ | Unclear
Quinn, 2011^92^ | Low risk
Rabinowitz, 2011^90^ | Low risk
Rabinowitz, 2012^91^ | Low risk
Rabinowitz, 2013^108^ | Low risk
Ross, 2013^110^ | High risk
Shipman, 2013^100^ | Low risk
Talley, 2011^87^ | Low risk
Whitacre, 2010^81^ | High risk
Zink, 2010^82^ | Unclear