# APPENDIX 2 LIST OF EXCLUDED STUDIES

This appendix lists the publications assessed as full text and not meeting inclusion criteria.

## BACKGROUND

A large number of publications did not meet inclusion criteria for the review but were retained as background information. Publications either reported more information on an included study (multiple publication), potentially contained sources of studies potentially meeting inclusion criteria, or were used in the introduction and discussion.

(2007). Challenges, solutions & opportunities : affordable housing, workforce training, recruitment & retention of health care professionals.
(2008). Shortage of general surgeons coming?. OR Manager.
(2012). Young physicians not keen on rural areas. Managed care (Langhorne, Pa.).
Aseltine RH, Katz MC, Geragosian AH. (2010). Connecticut 2009 Primary Care Survey: physician satisfaction, physician supply and patient access to medical care. Connecticut medicine.
Avery DM, Wheat JR, Leeper JD, McKnight JT, Ballard BG, Chen J. (2012). Admission factors predicting family medicine specialty choice: a literature review and exploratory study among students in the Rural Medical Scholars Program. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Baker E, Schmitz D, Epperly T, Nukui A, Miller CM. (2010). Rural Idaho Family Physicians' Scope of Practice. Journal of Rural Health.
Ballance D, Kornegay D, Evans P. (2009). Factors that influence physicians to practice in rural locations: a review and commentary. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Balshem H, Helfand M, Schunemann HJ, et al. (2011). GRADE guidelines: 3. Rating the quality of evidence. Journal of clinical epidemiology.
Barnighausen T, Bloom DE. (2009). Financial incentives for return of service in underserved areas: a systematic review. BMC health services research.
Barrett FA, Lipsky MS, Lutfiyya MN. (2011). The impact of rural training experiences on medical students: a critical review. Academic medicine : journal of the Association of American Medical Colleges.
Bowman RC. (2008). Measuring primary care: the standard primary care year. Rural Remote Health.
Bridgham RG. (2009). Final report : HB 1615, (Chapter 367:3, Laws of 2008), establishing a Commission to Recommend Policies and Programs to Increase the Number of New Hampshire Individuals in Health Professions Servicing New Hampshire's Rural and Underserved Areas with a Focus on Primary Care.
Broughan TA. (2008). SAGES 2007 rural surgery panel. Surgical endoscopy.
Carlton EL, Simmons LA. (2011). Health decision-making among rural women: physician access and prescription adherence. Rural Remote Health.
Chen C, Xierali I, Piwnica-Worms K, Phillips R. (2013). The redistribution of graduate medical education positions in 2005 failed to boost primary care or rural training. Health affairs (Project Hope).
Chipp C, Dewane S, Brems C, Johnson ME, Warner TD, Roberts LW. (2011). “If only someone had told me...”: lessons from rural providers. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Cogbill TH, Cofer JB, Jarman BT. (2012). Contemporary issues in rural surgery. Current problems in surgery.
Collier D. (2010). Rural Michigan physician retention study reveals motivators. Michigan medicine.
Cook AF, Hoas H. (2007). Hide and seek: The elusive rural psychiatrist. Academic Psychiatry.
Corbett CD. (2012). Recruitment and retention of physicians in rural North Dakota : testing for congruency between current policies and physician motivation. Dissertation: Paper (M.S.).
Crouse BJ, Munson RL. (2006). The effect of the physician J-1 visa waiver on rural Wisconsin. WMJ : official publication of the State Medical Society of Wisconsin.
Curran V, Rourke L, Snow P. (2010). A framework for enhancing continuing medical education for rural physicians: A summary of the literature. Medical teacher.
Deveney K, Deatherage M, Oehling D, Hunter J. (2013). Association between dedicated rural training year and the likelihood of becoming a general surgeon in a small town. JAMA surgery.
Dill MJ, Salsberg ES. (2008). The Complexities of Physician Supply and Demand: Projections Through 2025. November 2008.
Doescher MP, Andrilla CH, Skillman SM, Morgan P, Kaplan L. (2014). The contribution of physicians, physician assistants, and nurse practitioners toward rural primary care: findings from a 13-state survey. Medical care.
Dolea C, Stormont L, Braichet JM. (2010). Evaluated strategies to increase attraction and retention of health workers in remote and rural areas. Bull World Health Organ.
Dornan T, Littlewood S, Margolis SA, Scherpbier A, Spencer J, Ypinazar V. (2006). How can experience in clinical and community settings contribute to early medical education? A BEME systematic review. Med. Teach.
Dorsey ER, Nicholson S, Frist WH. (2011). Commentary: improving the supply and distribution of primary care physicians. Academic Medicine: Journal of the Association of American Medical Colleges.
Doty B, Andres M, Zuckerman R, Borgstrom D. (2009). Use of Locum Tenens Surgeons to Provide Surgical Care in Small Rural Hospitals. World J. Surg.
Doty B, Zuckerman R, Finlayson S, Jenkins P, Rieb N, Heneghan S. (2008). General surgery at rural hospitals: a national survey of rural hospital administrators. Surgery.
Edwards JB, Wilson JL, Behringer BA, et al. (2006). Practice locations of graduates of family physician residency and nurse practitioner programs: considerations within the context of institutional culture and curricular innovation through Titles VII and VIII. The Journal of rural health: official journal of the American Rural Health Association and the National Rural Health Care Association.
Escarce JJ, Kapur K. (2009). Do patients bypass rural hospitals? Determinants of inpatient hospital choice in rural California. J. Health Care Poor Underserved.
Everitt-Deering P. (2008). The adoption of information and communication technologies by rural general practitioners a socio technical analysis.
Filipova AA. (2014). Factors influencing the satisfaction of rural physician assistants: a cross-sectional study. Journal of allied health.
Fordyce MA, Chen FM, Doescher MP, Hart LG. (2007). 2005 physician supply and distribution in rural areas of the United States.
Fournier GM, Henderson C. (2005). Incentives and physician specialty choice: a case study of Florida's Program in Medical Sciences. Inquiry : a journal of medical care organization, provision and financing.
Fraher EP, Knapton A, Sheldon GF, Meyer A, Ricketts TC. (2013). Projecting surgeon supply using a dynamic model. Annals of surgery.
Gagnon MP, Pollender H, Trepanier A, Duplaa E, Ly BA. (2011). Supporting health professionals through information and communication technologies: a systematic review of the effects of information and communication technologies on recruitment and retention. Telemedicine journal and e-health : the official journal of the American Telemedicine Association.
Garrison-Jakel J. (2011). Patching the rural workforce pipeline--why don't we do more?. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Getson DS. (2013). Rural practice realities. The West Virginia medical journal.
Grobler L, Marais BJ, Mabunda SA, Marindi PN, Reuter H, Volmink J. (2009). Interventions for increasing the proportion of health professionals practising in rural and other underserved areas. The Cochrane database of systematic reviews.
Haggerty TS, Fields SA, Selby-Nelson EM, Foley KP, Shrader CD. (2013). Physician Wellness in Rural America: A Review. International journal of psychiatry in medicine.
Halaas GW. (2005). The Rural Physician Associate Program: successful outcomes in primary care and rural practice. Rural and remote health.
Henry LR, Hooker RS, Yates KL. (2011). The role of physician assistants in rural health care: a systematic review of the literature. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Hilty DM, Yellowlees PM, Cobb HC, Bourgeois JA, Neufeld JD, Nesbitt TS. (2006). Models of telepsychiatric consultation-liaison service to rural primary care. Psychosomatics.
Hirsh D, Walters L, Poncelet AN. (2012). Better learning, better doctors, better delivery system: possibilities from a case study of longitudinal integrated clerkships. Medical teacher.
Holmes GM. (2005). Increasing physician supply in medically underserved areas. Labour Econ.
Huff C. (2011). Where are the specialists?. Hospitals & health networks / AHA.
Huff C. (2012). Please doc, stay. Give docs a reason to set up shop. Hospitals & health networks / AHA.
Huff C. (2014). Done recruiting? Start retaining. Trustee : the journal for hospital governing boards.
Kochar MS. (2006). The J-1 visa waiver program for rural Wisconsin. WMJ : official publication of the State Medical Society of Wisconsin.
Larson EH, Hart LG. (2007). Growth and change in the physician assistant workforce in the United States, 1967-2000. Journal of allied health.
Lee DM, Nichols T. (2014). Physician recruitment and retention in rural and underserved areas. International journal of health care quality assurance.
Lindsay S. (2007). Gender differences in rural and urban practice location among mid-level health care providers. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Lynch S. (2013). Hospice and palliative care access issues in rural areas. The American journal of hospice & palliative care.
Lynge DC. (2008). Rural general surgeons: manpower and demographics. Surgical endoscopy.
Lynge DC, Larson EH, Thompson M, Rosenblatt RA, Hart LG. (2008). A longitudinal analysis of the general surgery workforce in the United States, 1981-2005. Arch. Surg.
MacDowell M, Glasser M, Fitts M, Fratzke M, Peters K. (2009). Perspectives on rural health workforce issues: Illinois-Arkansas comparison. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
MacDowell M, Glasser M, Fitts M, Nielsen K, Hunsaker M. (2010). A national view of rural health workforce issues in the USA. Rural and remote health.
MacDowell M, Glasser M, Hunsaker M. (2013). A decade of rural physician workforce outcomes for the Rockford Rural Medical Education (RMED) Program, University of Illinois. Academic medicine : journal of the Association of American Medical Colleges.
Maley M, Worley P, Dent J. (2009). Using rural and remote settings in the undergraduate medical curriculum: AMEE Guide No. 47. Med. Teach.
Mareck DG. (2011). Federal and state initiatives to recruit physicians to rural areas. The virtual mentor : VM.
Mbemba G, Gagnon MP, Pare G, Cote J. (2013). Interventions for supporting nurse retention in rural and remote areas: an umbrella review. Human resources for health.
Meyer D. (2006). Technology, job satisfaction, and retention: rural mental health practitioners. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Mullan F, Frehywot S, Jolley LJ. (2008). Aging, primary care, and self-sufficiency: health care workforce challenges ahead. The Journal of law, medicine & ethics : a journal of the American Society of Law, Medicine & Ethics.
Murphy KL. (2011). Alaska health care workforce shortages : impact of state legislation. Dissertation: Thesis (M.Public Health).
Nakayama DK, Hughes TG. (2014). Issues That Face Rural Surgery in the United States. Journal of the American College of Surgeons.
Nance ML, Carr BG, Branas CC. (2009). Access to pediatric trauma care in the United States. Archives of pediatrics & adolescent medicine.
Ortiz J, Bushy A, Zhou Y, Zhang H. (2013). Accountable care organizations: benefits and barriers as perceived by Rural Health Clinic management. Rural and remote health.
Palmer RT. (2014). Exploring online community among rural medical education students: A case study. Dissertation Abstracts International Section A: Humanities and Social Sciences.
Pathman DE. (2006). What outcomes should we expect from programs that pay physicians'training expenses in exchange for service?. North Carolina medical journal.
Pathman DE, Fryer GE, Phillips RL, Smucny J, Miyoshi T, Green LA. (2006). National Health Service Corps staffing and the growth of the local rural non-NHSC primary care physician workforce. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Patterson DG, Keppel G, Skillman SM, Berry C, Daniel C, Doescher MP. (2015). Recruitment of Non-U.S. Citizen Physicians to Rural and Underserved Areas through Conrad State 30 J-1 Visa Waiver Programs. Final Report #148, April 2015.
Patterson DG, Longenecker R, Schmitz D, Skillman SM, Doescher MP. (2011). Policy Brief: Training Physicians for Rural Practice: Capitalizing on Local Expertise to Strengthen Rural Primary Care.
Patterson DG, Longenecker R, Schmitz D, et al. (2012). January 2012 Policy Brief: Rural Residency Training for Family Medicine Physicians: Graduate Early-Career Outcomes.
Peterson LE, Bazemore A, Bragg EJ, Xierali I, Warshaw GA. (2011). Rural-urban distribution of the U.S. Geriatrics physician workforce. Journal of the American Geriatrics Society.
Philipp DL, Wright DL. (2005). Recruiting healthcare professionals to rural areas. Radiology management.
Price J. (2010). The National Health Service Corps--a critical component of provider recruitment in North Carolina's rural and underserved communities. North Carolina medical journal.
Quarry WA. (2012). A research study outlining the key issues and strategies needed to improve recruitment and retention among primary care physicians in rural communities.
Rabinowitz HK. (2011). AM last page. Truths about the rural physician supply. Academic medicine : journal of the Association of American Medical Colleges.
Rabinowitz HK, Diamond JJ, Markham FW, Rabinowitz C. (2005). Long-term retention of graduates from a program to increase the supply of rural family physicians. Academic medicine : journal of the Association of American Medical Colleges.
Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2011). Increasing the supply of women physicians in rural areas: outcomes of a medical school rural program. Journal of the American Board of Family Medicine : JABFM.
Rabinowitz HK, Diamond JJ, Markham FW, Santana AJ. (2012). The relationship between matriculating medical students' planned specialties and eventual rural practice outcomes. Academic medicine : journal of the Association of American Medical Colleges.
Rabinowitz HK, Diamond JJ, Markham FW, Wortman JR. (2008). Medical school programs to increase the rural physician supply: a systematic review and projected impact of widespread replication. Academic medicine : journal of the Association of American Medical Colleges.
Ricketts TC. (2005). Workforce issues in rural areas: A focus on policy equity. Am. J. Public Health.
Roh CY, Moon MJ. (2005). Nearby, but not wanted? The bypassing of rural hospitals and policy implications for rural health care systems. Policy Stud. J.
Rosenblatt RA, Andrilla CH, Curtin T, Hart LG. (2006). Shortages of medical personnel at community health centers: implications for planned expansion. Jama.
Schmitz DF, Baker E, Nukui A, Epperly T. (2011). Idaho rural family physician workforce study: the Community Apgar Questionnaire. Rural and remote health.
Seligson RW, Highsmith PP. (2006). North Carolina Medical Society Foundation's Community Practitioner Program. North Carolina medical journal.
Staton FS, Bhosle MJ, Camacho FT, Feldman SR, Balkrishnan R. (2007). How PAs improve access to care for the underserved. JAAPA : official journal of the American Academy of Physician Assistants.
Stempniak M. (2012). The hiring headache. Rural hospitals band together to lure physicians. Hospitals & health networks / AHA.
Thompson MJ, Hagopian A, Fordyce M, Hart LG. (2009). Do international medical graduates (IMGs) “fill the gap” in rural primary care in the United States? A national study. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Thompson MJ, Lynge DC, Larson EH, Tachawachira P, Hart LG. (2005). Characterizing the general surgery workforce in rural America. Archives of surgery (Chicago, Ill: 1960).
Toner JA, Ferguson KD, Sokal RD. (2009). Continuing interprofessional education in geriatrics and gerontology in medically underserved areas. Journal of Continuing Education in the Health Professions.
Traverso G, McMahon GT. (2012). Residency training and international medical graduates: Coming to America no more. JAMA: Journal of the American Medical Association.
Tumosa N, Horvath KJ, Huh T, et al. (2012). Health care workforce development in rural america: when geriatrics expertise is 100 miles away. Gerontology & geriatrics education.
Van Vleet A, Paradise J. (2015). Issue Brief: Tapping Nurse Practitioners to Meet Rising Demand for Primary Care.
Vogt HB. (2008). South Dakota's rural physician shortage: how might it be addressed?. South Dakota medicine : the journal of the South Dakota State Medical Association.
Wade ME, Brokaw JJ, Zollinger TW, et al. (2007). Influence of hometown on family physicians' choice to practice in rural settings. Family medicine.
Walters L, Greenhill J, Richards J, et al. (2012). Outcomes of longitudinal integrated clinical placements for students, clinicians and society. Medical Education.
Weeks WB, Wallace AE, West AN, Heady HR, Hawthorne K. (2008). Research on rural veterans: An analysis of the literature. Journal of Rural Health.
Weldon T. (2008). Physician shortages and the medically underserved. Trends in America; Variation: Trends in America.
Wheat JR, Higginbotham JC, Yu J, Leeper JD. (2005). Physicians for rural America: the role of institutional commitment within academic medical centers. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Whitcomb ME. (2005). The challenge of providing doctors for rural America. Academic medicine : journal of the Association of American Medical Colleges.
Wilson NW, Couper ID, De Vries E, Reid S, Fish T, Marais BJ. (2009). A critical review of interventions to redress the inequitable distribution of healthcare professionals to rural and remote areas. Rural and remote health.
Xierali IM, Sweeney SA, Phillips RL, Bazemore AW, Petterson SM. (2012). Increasing graduate medical education (GME) in critical access hospitals (CAH) could enhance physician recruitment and retention in rural America. Journal of the American Board of Family Medicine : JABFM.
Zuckerman R, Doty B, Gold M, et al. (2006). General surgery programs in small rural New York state hospitals: A pilot survey of hospital administrators. Journal of Rural Health.
Zurn P, Vujicic M, Lemiere C, et al. (2011). A technical framework for costing health workforce retention schemes in remote and rural areas. Human resources for health.

## DESIGN

Publications excluded based on the study design, (eg, the publication did not report on empirical data)

(2005). Shortages of rural generalist physicians may be due to poor recruitment rather than retention problems. AHRQ Research Activities.
Barr P. (2012). Looking for an oasis: large sections of rural America continue to suffer from a drought of general surgeons. Mod Healthc.
Basco WT, Rimsza ME. (2013). Pediatrician workforce policy statement. Pediatrics.
Behringer B, Friedell GH. (2006). Appalachia: where place matters in health. Preventing chronic disease.
Bellinger N. (2009). Predictors of primary care physicians practicing in medically underserved and rural areas of Indiana. Variation: IUPUI theses and dissertations.
Berens D. (2006). Recruitment or retention: J-1 visa lessons. WMJ : official publication of the State Medical Society of Wisconsin.
Brooks KD, Cieslak JE, Radcliffe PM, Sjogren K. (2008). Primary care in Minnesota: an academic health center's perspective. Minnesota medicine.
Calman NS, Hauser D, Forte G, Continelli T. (2007). New York State physicians: characteristics and distribution in health professional shortage areas. Journal of urban health : bulletin of the New York Academy of Medicine.
Casaletto JJ, Wadman MC, Ankel FK, Bourne CL, Ghaemmaghami CA. (2013). Emergency Medicine Rural Rotations: A Program Director's Guide. Annals of emergency medicine.
Casey BR, Owens J, Gross DA, Dixon LM. (2005). Rural Kentucky's physician shortage: strategies for producing, recruiting, and retaining primary care providers within a medically underserved region. The Journal of the Kentucky Medical Association.
Chen F, Hart LG. (2006). Another look at rural health. Health affairs (Project Hope).
Chewning LH, Spade J. (2007). Rural hospitals and rural physicians: understanding the physician workforce challenges that affect rural communities and providers. North Carolina medical journal.
Click IA. (2014). Practice characteristics of graduates of east tennessee state university quillen college of medicine: Factors related to career choices in primary care. Dissertation Abstracts International Section A: Humanities and Social Sciences.
Cofer JB, Burns RP. (2008). The developing crisis in the national general surgery workforce. Journal of the American College of Surgeons.
Cofer JB, Petros TJ, Burkholder HC, Clarke PC. (2011). General Surgery at Rural Tennessee Hospitals: A Survey of Rural Tennessee Hospital Administrators. Am. Surg.
Colgan R, Lewin L, Southall N, Williams M, Baquet C. (2011). University of Maryland School of Medicine increases medical student education in primary care. Maryland medicine : MM : a publication of MEDCHI, the Maryland State Medical Society.
Collins S. (2012). Primary care shortages: strengthening this sector is urgently needed, now and in preparation for healthcare reform. American health & drug benefits.
Danto LA. (2010). National rural health service. Bulletin of the American College of Surgeons.
Edgerly D. (2013). Rural Colorado care. West Routt Fire Protection District provides BLS & ALS. JEMS : a journal of emergency medical services.
Emery JG. (2012). Comment on: Medical students on long-term regional and rural placements: what is the financial cost to supervisors?. Rural and remote health.
Farmer D. (2013). Rural surgery is global surgery: seeking solutions to the growing surgical workforce crisis. JAMA surgery.
Farrell PM. (2005). Plan to address physician shortage requires proper support. WMJ : official publication of the State Medical Society of Wisconsin.
Ferguson WJ, Cashman SB, Savageau JA, Lasser DH. (2009). Family Medicine Residency Characteristics Associated With Practice in a Health Professions Shortage Area. Fam. Med.
Galloro V. (2008). Hard recruitment for smaller markets. Report shows importance of physicians to rural hospitals' financial health. Mod Healthc.
Garpestad B. (2009). Funding for frontier home care: an anatomy of Montana's rural health care. Caring.
Glasser M, Peters K, Macdowell M. (2006). Rural Illinois hospital chief executive officers' perceptions of provider shortages and issues in rural recruitment and retention. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Greenhill J, Poncelet AN. (2013). Transformative learning through longitudinal integrated clerkships. Medical education.
Gunn J. (2013). Minnesota's rural health workforce shortages. Minnesota medicine.
Halaas GW. (2005). The Rural Physician Associate Program: new directions in education for competency. Rural and remote health.
Handel DA, Hedges JR. (2007). Improving rural access to emergency physicians. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine.
Heady HR, Phillips D, Briggs E. (2006). Rural healthcare: how to recruit and retain health professionals. The Journal of medical practice management : MPM.
Hooker RS, Klocko DJ, Larkin GL. (2011). Physician Assistants in Emergency Medicine: The Impact of Their Role. Academic Emergency Medicine.
Huff C. (2012). Give docs a reason to set up shop. H&HN: Hospitals & Health Networks.
Huff C. (2014). You got the docs, now keep them! 5 strategies for rural hospitals to help retain their hard-won physicians. Hospitals & health networks / AHA.
Huffstutter PJ. (2010). Rural surgeons--we must grow our own. Bulletin of the American College of Surgeons.
Johna S. (2006). The rural surgeon: an endangered species. World J Surg.
Johnson CA, Johnson BE. (2008). Family medicine practice in rural any-country. Family medicine.
Kane KY, Quinn KJ, Stevermer JJ, et al. (2013). Summer in the country: changes in medical students' perceptions following an innovative rural community experience. Academic medicine : journal of the Association of American Medical Colleges.
Kirschling JM, Horvey-McPherson L, Curley D. (2008). Maine's nursing workforce legislation: Lessons from a rural state. Nurs. Outlook.
Kutscher B. (2013). The rural route. Hospitals in underserved areas taking different roads to recruit, retain physicians. Mod Healthc.
Lasher WF, Silverman SB. (2008). Relationship between residency training and practice location in primary care residency programs in Texas.
Lauver LS, Swan BA, West MM, et al. (2011). Kids Into Health Careers: A Rural Initiative. Journal of Rural Health.
Longo WE, Sumpio B, Duffy A, Seashore J, Udelsman R. (2008). Early specialization in surgery: the new frontier. The Yale journal of biology and medicine.
Lynge DC, Larson EH. (2009). Workforce issues in rural surgery. The Surgical clinics of North America.
Mantone J. (2005). Protective moves. Caps may lure docs to rural communities: study. Mod Healthc.
Margolis SA. (2005). Retaining rural medical practitioners: time for a new paradigm?. Rural and remote health.
Margolis SA. (2005). Letter to the editor Retaining rural medical practitioners: time for a new paradigm?. Rural & Remote Health.
McHugh G, Stewart G. (2010). Regional and rural specialists. Anaesthesia and intensive care.
Mobley J, Zuniga MA. (2012). Training primary care physicians for local health authority duties in Texas. American journal of public health.
Morley CP. (2012). Supporting Physicians Who Work in Challenging Contexts: A Role for the Academic Health Center. J. Am. Board Fam. Med.
Nelson BV, Talboy GE. (2010). Acute care surgery: redefining the general surgeon. Missouri medicine.
Nocella IC. (2005). Recruitment of family physicians into rural California : predictors and possibilities.
Nusbaum N. (2009). Commentary: Physician retirement and physician shortages. Journal of Community Health.
O'Brien ML. (2008). Perception of rural caregiving. Dissertation: Thesis (MS).
Oklahoma. Physician Manpower Training C. (2012). Oklahoma Medical Loan Repayment Program.
Page S, Birden H. (2008). Twelve tips on rural medical placements: what has worked to make them successful. Medical teacher.
Penn CL. (2006). Now hiring! Arkansas, like the nation, faces imminent health care worker shortages. The Journal of the Arkansas Medical Society.
Potter AJ, Mueller KJ, Mackinney AC, Ward MM. (2014). Effect of tele-emergency services on recruitment and retention of US rural physicians. Rural and remote health.
Prengaman MP, Bigbee JL, Baker E, Schmitz DF. (2014). Development of the Nursing Community Apgar Questionnaire (NCAQ): a rural nurse recruitment and retention tool. Rural Remote Health.
Quinn KJ. (2012). Experiences influencing physician rural practice and retention: A phenomenological study. Dissertation Abstracts International Section A: Humanities and Social Sciences.
Rabinowitz HK. (2009). Addressing physician specialty maldistribution. Jama.
Ricketts TC, Walker E. (2010). Health reform and workforce: the North Carolina connection. North Carolina medical journal.
Robertson JE, Boyd J, Hedges JR, Keenan EJ. (2007). Strategies for increasing the physician workforce: the Oregon model for expansion. Academic medicine : journal of the Association of American Medical Colleges.
Rosenblatt RA. (2010). Commentary: do medical schools have a responsibility to train physicians to meet the needs of the public? The case of persistent rural physician shortages. Academic medicine : journal of the Association of American Medical Colleges.
Rourke J. (2010). How can medical schools contribute to the education, recruitment and retention of rural physicians in their region?. Bull World Health Organ.
Schein M. (2006). Editorial comment: Surgery in rural America. World J Surg.
Scutchfield FD. (2009). Increasing the medical school application pool: a key to training more rural physicians. The Journal of the Kentucky Medical Association.
Sharp DB. (2010). Factors related to the recruitment and retention of nurse practitioners in rural areas.
Sheldon GF. (2009). Surgical practice in rural areas. Introduction. The Surgical clinics of North America.
Smith RJ. (2008). Frontier residents' perception of health care access.
Stempniak M. (2012). Rural hospitals band together to lure physicians. H&HN: Hospitals & Health Networks.
Steptoe AP, Sullivan AF, Rogers J, Ginde AA, Camargo CA. (2010). Factors In Recruiting and Retaining Emergency Physicians to Rural Emergency Departments. Annals of emergency medicine.
Stevens CB. (2012). The dilemma of the rural psychiatrist. Journal of Psychiatric Practice.
Sumaya CV, Opara CM, Espino DV. (2013). The Geriatrician and Geriatric Psychiatrist Workforce in Texas: Characteristics, Challenges, and Policy Implications. J. Aging Health.
Szabo J. (2011). Rural hospitals look near and far for allied health professionals. Hospitals & health networks / AHA.
Thrall TH. (2007). Physician recruitment. Encouraging med students to return to rural areas. Hospitals & health networks / AHA.
Thrall TH. (2008). Physician recruitment. Garrison Keillor: doctor magnet. Hospitals & health networks / AHA.
Tong STC, Makaroff LA, Xierali IM, et al. (2012). Proportion of Family Physicians Providing Maternity Care Continues to Decline. J. Am. Board Fam. Med.
Turlington AR. (2008). Barriers to rural mental health care: Perspectives from those who live there. Dissertation Abstracts International: Section B: The Sciences and Engineering.
Wakefield M, Amundson M, Moulton P, Gibbens B. (2007). Policy brief: North Dakota Health Care Workforce: planning together to meet future health care needs. The Prairie rose.
Welch JP. (2008). Whither goest general surgery?. Archives of surgery.
Westergaard RP, Stockman LJ, Hyland HA, Guilfoyle SM, Fangman JJ, Vergeront JM. (2014). Provider Workforce Assessment in a Rural Hepatitis C Epidemic: Implications for Scale-up of Antiviral Therapy. Journal of primary care & community health.
Zastrow AW. (2006). Dilemma of general surgery recruitment in rural America. World J Surg.
Zigmond J. (2006). Help wanted. Benefits include an idyllic rural setting, a friendly community and some assistance paying off those hefty medical school loans. Mod Healthc.
Zuckerman RS. (2008). Rural surgery and surgical education. Surgical endoscopy.
Zukowsky K, Swan BA, Powell M, et al. (2011). Implementing an MSN nursing program at a distance through an urban-rural partnership. Advances in neonatal care : official journal of the National Association of Neonatal Nurses.

## DUPLICATE

Publications excluded because they are identical to another citation in the database.

Quinn KJHJL. (2009). Experiences influencing physician rural practice and retention a phenomenological study. Dissertation: Ph D.

## INTERVENTION

Publications excluded due to the intervention (the publication did not report on an intervention or did not report on an intervention relevant to provider recruitment or retention).

Anderson DM, Whitler ET, Johnson AO, Elam CL, Wilson EA, Asher LM. (2009). Increasing the medical school applicant pool: a key to training more rural physicians. The Journal of the Kentucky Medical Association.
Casey MM, Hung PY, Moscovice I, Prasad S. (2014). The Use of Hospitalists by Small Rural Hospitals: Results of a National Survey. Med. Care Res. Rev.
Rodney WM, Martinez C, Collins M, Laurence G, Pean C, Stallings J. (2010). OB Fellowship Outcomes 1992-2010: Where Do They Go, Who Stops Delivering, and Why? Fam. Med.
Singh R, Mathiassen L, Stachura ME, Astapova EV. (2010). Sustainable Rural Telehealth Innovation: A Public Health Case Study. Health Serv. Res.

## OUTCOME

A large number of studies were excluded because they did not report on healthcare provider recruitment or retention measures.

Allen JEt, Davis AF, Hu W, Owusu-Amankwah E. (2015). Residents' Willingness-to-Pay for Attributes of Rural Health Care Facilities. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Allen SM, Ballweg RA, Cosgrove EM, et al. (2013). Challenges and opportunities in building a sustainable rural primary care workforce in alignment with the Affordable Care Act: the WWAMI program as a case study. Academic medicine : journal of the Association of American Medical Colleges.
Arora S, Kalishman S, Dion D, et al. (2011). Partnering Urban Academic Medical Centers And Rural Primary Care Clinicians To Provide Complex Chronic Disease Care. Health Affairs.
Beverly EA, Reynolds S, Balbo JT, Adkins S, Longenecker R. (2014). Changing first-year medical students' attitudes toward primary care. Family medicine.
Bing-You RG, Bates PW, Epstein SK, Kuhlik AB, Norris TE. (2010). Using decentralized medical education to address the workforce needs of a rural state: a partnership between Maine Medical Center and Tufts University school of medicine. Rural and remote health.
Borgstrom DC, Heneghan SJ. (2009). Bassett healthcare rural surgery experience. The Surgical clinics of North America.
Breedlove G, Lamping B, Smith JA. (2006). The Kansas Health Education Training Center: caring for the underserved. Kansas Nurse.
Breon TA. (2009). Rural surgical practice: an Iowa group model. The Surgical clinics of North America.
Brooks KD, Eley DS, Zink T. (2014). Profiles of rural longitudinal integrated clerkship students: a descriptive study of six consecutive student cohorts *. Medical teacher.
Bushardt RL, Whitt FK, Gregory T. (2014). Training physician assistants for rural Appalachia: an academic partnership for interprofessional collaboration. North Carolina medical journal.
Canon S, Shera A, Patel A, et al. (2014). A pilot study of telemedicine for post-operative urological care in children. Journal of telemedicine and telecare.
Cheng D, Fernandez J. (2005). Emergency medicine residency underrepresentation in rural states. The American journal of emergency medicine.
Cogbill TH, Jarman BT. (2009). Rural general surgery training: the Gundersen Lutheran approach. The Surgical clinics of North America.
Colegrove DJ, Whitacre BE. (2009). Interest in rural medicine among osteopathic residents and medical students. Rural and remote health.
Colon-Gonzalez MC, McCall-Hosenfeld JS, Weisman CS, Hillemeier MM, Perry AN, Chuang CH. (2013). “Someone's got to do it” - Primary care providers (PCPs) describe caring for rural women with mental health problems. Mental health in family medicine.
Colwill JM, Cultice JM, Kruse RL. (2008). Will generalist physician supply meet demands of an increasing and aging population?. Health affairs (Project Hope).
Conger MM, Plager KA. (2008). Advanced nursing practice in rural areas: connectedness versus disconnectedness. Online Journal of Rural Nursing & Health Care.
Cook AF, Hoas H. (2008). Ethics and rural healthcare: what really happens? What might help?. American Journal of Bioethics.
Cook MR, Yoon M, Hunter J, Kwong KR, Kiraly L. (2015). A nonmetropolitan surgery clerkship increases interest in a surgical career. Am. J. Surg.
Cosgrove EM, Harrison GL, Kalishman S, et al. (2007). Addressing physician shortages in New Mexico through a combined BA/MD program. Academic medicine : journal of the Association of American Medical Colleges.
Crump WJ, Fricker RS, Crump AM. (2010). Just what are rural premedical students thinking? A report of the first 6 years of a pathways program. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Decker MR, Bronson NW, Greenberg CC, Dolan JP, Kent KC, Hunter JG. (2013). The General Surgery Job Market: Analysis of Current Demand for General Surgeons and Their Specialized Skills. Journal of the American College of Surgeons.
Dehn RW. (2008). Workforce issues impacting PAs. JAAPA: Journal of the American Academy of Physician Assistants.
DeKastle R. (2009). Telesurgery: providing remote surgical observations for students. AORN Journal.
Dennison DA, Yin Z, Kibbe D, Burns S, Trowbridge F. (2008). Training health care professionals to manage overweight adolescents: experience in rural Georgia communities. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Dent MM, Mathis MW, Outland M, Thomas M, Industrious D. (2010). Chronic disease management: teaching medical students to incorporate community. Family medicine.
Deutchman ME, Nearing K, Baumgarten B, Westfall JM. (2012). Interdisciplinary rural immersion week. Rural and remote health.
Dick JF, Wilper AP, Smith S, Wipf J. (2011). The effect of rural training experiences during residency on the selection of primary care careers: a retrospective cohort study from a single large internal medicine residency program. Teaching and learning in medicine.
Donnon T, Woloschuk W, Myhre D. (2009). Issues related to medical students' engagement in integrated rural placements: an exploratory factor analysis. Journal canadien de la medecine rurale : le journal officiel de la Societe de medecine rurale du Canada.
Downey LH, Wheat JR, Leeper JD, Florence JA, Boulger JG, Hunsaker ML. (2011). Undergraduate rural medical education program development: focus group consultation with the NRHA Rural Medical Educators Group. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Fannin JM, Barnes JN. (2007). Recruitment of physicians to rural America: a view through the lens of Transaction Cost Theory. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Felix HC, Wootten EB, Stewart MK. (2005). The Arkansas Southern Rural Access Program: strategies for improving health care in rural areas of the state. The Journal of the Arkansas Medical Society.
Foster PP, Williams JH, Estrada CA, et al. (2010). Recruitment of rural physicians in a diabetes internet intervention study: overcoming challenges and barriers. Journal of the National Medical Association.
Freed GL, Dunham KM, Loveland-Cherry C, Martyn KK. (2010). Family Nurse Practitioners: Roles and Scope of Practice in the Care of Pediatric Patients. Pediatrics.
Frellick M. (2011). The nurse practitioner will see you now. Advanced practice providers fill the physician gap. Hospitals & health networks / AHA.
Frintner MP, Cull WL. (2012). Pediatric training and career intentions, 2003–2009. Pediatrics.
Frintner MP, Mulvey HJ, Pletcher BA, Olson LM. (2013). Pediatric resident debt and career intentions. Pediatrics.
Gazewood JD, Rollins LK, Galazka SS. (2006). Beyond the horizon: the role of academic health centers in improving the health of rural communities. Academic medicine : journal of the Association of American Medical Colleges.
Geske JA, Hartman T, Goodman B, Paulman P. (2011). Influence of a rural family medicine rotation on residency selection: MS3 versus MS4. Family medicine.
Giles WH, Arnold JD, Layman TS, et al. (2009). Education of the rural surgeon: experience from Tennessee. The Surgical clinics of North America.
Gillman LM, Vergis A. (2013). General surgery graduates may be ill prepared to enter rural or community surgical practice. American journal of surgery.
Groth H, House H, Overton R, Deroo E. (2013). Board-certified emergency physicians comprise a minority of the emergency department workforce in iowa. The western journal of emergency medicine.
Halaas GW, Zink T, Brooks KD, Miller J. (2007). Clinical skills day: preparing third year medical students for their rural rotation. Rural and remote health.
Heidelbaugh J, Cooke J, Wimsatt L. (2013). Opportunities for medical student engagement with family medicine. Family medicine.
Hilty DM, Marks S, Wegelin J, Callahan EJ, Nesbitt TS. (2007). A randomized, controlled trial of disease management modules, including telepsychiatric care, for depression in rural primary care. Psychiatry.
Hughes S, Zweifler JA, Garza A, Stanich MA. (2008). Trends in rural and urban deliveries and vaginal births: California 1998-2002. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Kaplan L, Brown M, Andrilla CH, Hart LG. (2009). Rural-urban practice patterns of nurse practitioners in Washington State. Journal for Nurse Practitioners.
Keenum AJ, Rawlings LM, Odoi A, et al. (2013). Tennessee emergency medicine workforce, 2009. Tennessee medicine : journal of the Tennessee Medical Association.
Kemper L, Barker AR, McBride TD, Mueller K. (2014). 2012 rural Medicare Advantage quality ratings and bonus payments. Rural policy brief.
Kippenbrock T, Buron B, Odell E, Narcisse MR. (2014). Minimal Changes and Missed Opportunities: A Decade Look at Nurse Practitioners in the Lower Mississippi River Delta States. Journal of Professional Nursing.
Kosteniuk J, Morgan D, Innes A, et al. (2014). Who steers the ship? Rural family physicians' views on collaborative care models for patients with dementia. Primary health care research & development.
Laditka JN, Laditka SB, Probst JC. (2005). More may be better: evidence of a negative relationship between physician supply and hospitalization for ambulatory care sensitive conditions. Health services research.
Li P, Ward MM, Schneider JE. (2009). Factors associated with Iowa rural hospitals' decision to convert to critical access hospital status. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Lindeke L, Jukkala A, Tanner M. (2005). Perceived barriers to nurse practitioner practice in rural settings. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Liu JJ, Bellamy G, Barnet B, Weng S. (2008). Bypass of local primary care in rural counties: effect of patient and community characteristics. Ann. Fam. Med.
Longo DR, Gorman RJ, Ge B. (2005). Rural medical school applicants: do their academic credentials and admission decisions differ from those of nonrural applicants?. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Macy ML, Butchart AT, Singer DC, Gebremariam A, Clark SJ, Davis MM. (2014). Looking Back on Rear-Facing Car Seats: Surveying US Parents in 2011 and 2013. Academic pediatrics.
Makaroff LA, Xierali IM, Petterson SM, Shipman SA, Puffer JC, Bazemore AW. (2014). Factors Influencing Family Physicians' Contribution to the Child Health Care Workforce. Ann. Fam. Med.
Marth NJ. (2010). Advanced practice registered nurse (APRN) supply in a rural state : trends to inform policy.
McCollister HM, Severson PA, LeMieur TP, Roberts SA, Gujer MW. (2009). Building and maintaining a successful surgery program in rural Minnesota. The Surgical clinics of North America.
Miller BF, Petterson S, Brown Levey SM, Payne-Murphy JC, Moore M, Bazemore A. (2014). Primary care, behavioral health, provider colocation, and rurality. Journal of the American Board of Family Medicine : JABFM.
Mistretta MJ. (2007). Differential effects of economic factors on specialist and family physician distribution in Illinois: a county-level analysis. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Moesinger R, Hill B. (2009). Establishing a rural surgery training program: a large community hospital, expert subspecialty faculty, specific goals and objectives in each subspecialty, and an academic environment lay a foundation. Journal of surgical education.
Mohr NM, Collier J, Hassebroek E, Groth H. (2014). Characterizing critical care physician staffing in rural America: a description of Iowa intensive care unit staffing. J Crit Care.
Mueller KJ, Potter AJ, MacKinney AC, Ward MM. (2014). Lessons From Tele-Emergency: Improving Care Quality And Health Outcomes By Expanding Support For Rural Care Systems. Health Affairs.
Murphy KL, Kobayashi D, Golden SL, Nageswaran S. (2012). Rural and nonrural differences in providing care for children with complex chronic conditions. Clin Pediatr (Phila).
Nation CL, Gerstenberger A, Bullard D. (2007). Preparing for change: the plan, the promise, and the parachute. Academic medicine : journal of the Association of American Medical Colleges.
Nelson RE, Battistone MJ, Ashworth WD, et al. (2014). Cost effectiveness of training rural providers to perform joint injections. Arthritis care & research.
Overman BA, Petri L, Knoki-Wilson U. (2007). A view from inside Arizona and New Mexico Indian country: pursuing a health career path. Rural and remote health.
Owen JA, Conaway MR, Bailey BA, Hayden GF. (2007). Predicting rural practice using different definitions to classify medical school applicants as having a rural upbringing. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Pathman DE, Morgan JC, Konrad TR, Goldberg L. (2012). States' Experiences With Loan Repayment Programs for Health Care Professionals in a Time of State Budget Cuts and NHSC Expansion. Journal of Rural Health.
Pathman DE, Ricketts TC. (2009). Interdependence of general surgeons and primary care physicians in rural communities. The Surgical clinics of North America.
Petelin JB, Nelson ME, Goodman J. (2007). Deployment and early experience with remote-presence patient care in a community hospital. Surgical endoscopy.
Phillips RL, Bazemore AW, Dodoo MS, Shipman SA, Green LA. (2006). Family physicians in the child health care workforce: opportunities for collaboration in improving the health of children. Pediatrics.
Pretorius RW, Milling DA, McGuigan D. (2008). Influence of a rural background on a medical student's decision to specialize in family medicine. Rural and remote health.
Ray TE. (2014). Perceptions of Nurse Practitioners on Rural and Remote Health Care Practice. Walden University.
Rayman KM, Edwards J. (2010). Rural primary care providers' perceptions of their role in the breast cancer care continuum. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Reed AJ, Schmitz D, Baker E, Nukui A, Epperly T. (2012). Association of “Grit” and Satisfaction in Rural and Nonrural Doctors. J. Am. Board Fam. Med.
Reschovsky JD, Staiti AB. (2005). Access and quality: does rural America lag behind?. Health affairs (Project Hope).
Rhoads Kinder SJ, Cherepski A, Freeman K. (2014). E-Learning in Obstetrics and HIV: Utilizing Online Interactive Scenarios to Replicate Critical Decision Making Moments. JOGNN: Journal of Obstetric, Gynecologic & Neonatal Nursing.
Richardson I, Slifkin R, Randolph R, Holmes GM. (2010). A rural-urban comparison of allied health professionals' average hourly wage. Journal of allied health.
Ricketts TC. (2013). The migration of physicians and the local supply of practitioners: a five-year comparison. Academic medicine : journal of the Association of American Medical Colleges.
Ricketts TC, Randolph R. (2007). Urban-rural flows of physicians. Journal of Rural Health.
Ricketts TC, Randolph R. (2008). The diffusion of physicians. Health Affairs.
Rittenhouse DR, Fryer GE, Phillips RL, et al. (2008). Impact of Title VII training programs on community health center staffing and national health service corps participation. Annals of family medicine.
Roh CY, Lee KH, Fottler MD. (2008). Determinants of hospital choice of rural hospital patients: the impact of networks, service scopes, and market competition. Journal of medical systems.
Roseamelia C, Greenwald JL, Bush T, Pratte M, Wilcox J, Morley CP. (2014). A Qualitative Study of Medical Students in a Rural Track: Views on Eventual Rural Practice. Fam. Med.
Rosenblatt RA, Hagopian A, Andrilla CH, Hart G. (2006). Will rural family medicine residency training survive?. Family medicine.
Rossi A, Rossi D, Rossi M, Rossi P. (2011). Continuity of care in a rural critical access hospital: Surgeons as primary care providers. Am. J. Surg.
Royston PJ, Mathieson K, Leafman J, Ojan-Sheehan O. (2012). Medical student characteristics predictive of intent for rural practice. Rural Remote Health.
Sawyer BT, Ginde AA. (2014). Scope of practice and autonomy of physician assistants in rural versus urban emergency departments. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine.
Schwartz MR. (2008). The physician pipeline to rural and underserved areas in Pennsylvania. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Seidel RW, Kilgus MD. (2014). Agreement between telepsychiatry assessment and face-to-face assessment for Emergency Department psychiatry patients. J. Telemed. Telecare.
Shannon CK. (2006). A gender-based study of attitudes and practice characteristics of rural physicians in West Virginia. The West Virginia medical journal.
Shannon CK, Baker H, Jackson J, Roy A, Heady H, Gunel E. (2005). Evaluation of a required statewide interdisciplinary Rural Health Education Program: student attitudes, career intents and perceived quality. Rural and remote health.
Shapiro J, Longenecker R. (2005). Country doctors in literature: helping medical students understand what rural practice is all about. Academic medicine : journal of the Association of American Medical Colleges.
Sirinek KR, Willis R, Stewart RM. (2014). Geographic maldistribution of general surgery PGYI residents: another US surgical desert. Am. J. Surg.
Slagle DR, Byington RL, Verhovsek EL. (2012). Rural Versus Urban: Tennessee Health Administrators' Strategies on Recruitment and Retention for Allied Health Professionals. Journal of Health Care Finance.
Smoot RL, Farley DR. (2006). Minnesota general surgeons. Where do they come from? Minnesota medicine.
Snyder CL. (2008). Temporal geomapping of pediatric surgeons in the United States. Journal of pediatric surgery.
Stingley S, Schultz H. (2014). Helmsley Trust Support For Telehealth Improves Access To Care In Rural And Frontier Areas. Health Affairs.
Tatkon-coker AL. (2007). The relationship of medicare and medicaid reimbursement on job dissatisfaction and spousal influence on the retention of rural health practitioners in North Central Iowa and South Central Minnesota. Dissertation: Thesis (DBA).
Toner JA, Ferguson KD, Sokal RD. (2009). Continuing interprofessional education in geriatrics and gerontology in medically underserved areas. Journal of Continuing Education in the Health Professions.
Tong ST, Makaroff LA, Xierali IM, Puffer JC, Newton WP, Bazemore AW. (2013). Family physicians in the maternity care workforce: factors influencing declining trends. Maternal and child health journal.
Vanleit B, Cubra J. (2005). Student-developed problem-based learning cases: preparing for rural healthcare practice. Rural and remote health.
Wadman MC, Hoffman LH, Erickson T, Tran TP, Muelleman RL. (2007). The impact of a rural emergency department rotation on applicant ranking of a US emergency medicine residency program. Rural & Remote Health.
Wayne SJ, Kalishman S, Jerabek RN, Timm C, Cosgrove E. (2010). Early predictors of physicians' practice in medically underserved communities: a 12-year follow-up study of University of New Mexico School of Medicine graduates. Academic medicine : journal of the Association of American Medical Colleges.
Weeks WB, Wallace AE. (2008). Rural-urban differences in primary care physicians' practice patterns, characteristics, and incomes. Journal of Rural Health.
Wheat JR, Leeper JD, Brandon JE, Guin SM, Jackson JR. (2011). The Rural Medical Scholars Program Study: Data to Inform Rural Health Policy. J. Am. Board Fam. Med.
Wimmer P. (2007). Professionalism among medical practitioners a case study of rural physicians.
Wolf L, Delao AM. (2013). Identifying the Educational Needs of Emergency Nurses in Rural and Critical Access Hospitals. J. Contin. Educ. Nursing.
Wright DB. (2009). Care in the country: a historical case study of long-term sustainability in 4 rural health centers. Am. J. Public Health.
Xu X, Siefert KA, Jacobson PD, Lori JR, Gueorguieva I, Ransom SB. (2009). Malpractice burden, rural location, and discontinuation of obstetric care: a study of obstetric providers in Michigan. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Zayas LE, McGuigan D. (2006). Experiences promoting healthcare career interest among high-school students from underserved communities. J. Natl. Med. Assoc.
Zink T, Halaas GW, Brooks KD. (2009). Learning professionalism during the third year of medical school in a 9-month-clinical rotation in rural Minnesota. Medical teacher.
Zink T, Halaas GW, Finstad D, Brooks KD. (2008). The rural physician associate program: the value of immersion learning for third-year medical students. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Zink T, Power DV, Finstad D, Brooks KD. (2010). Is there equivalency between students in a longitudinal, rural clerkship and a traditional urban-based program?. Family medicine.

## PARTICIPANTS

Publications excluded because they did not report on healthcare providers or reported on providers outside the scope of the review.

Amerson RMGLS, thesis a. (2012). Understanding the occupational choices of rural white southern males. Dissertation: Ed. D.
Bradbury GB. (2013). Retention of staff nurses in a rural hospital setting in the eastern part of North Carolina: The impact of leadership style.
Bratt MM. (2009). Retaining the next generation of nurses: the Wisconsin nurse residency program provides a continuum of support. J Contin Educ Nurs.
Cramer M, Nienaber J, Helget P, Agrawal S. (2006). Comparative analysis of urban and rural nursing workforce shortages in Nebraska hospitals. Policy, politics & nursing practice.
Crump WJ, Fricker RS, Flick KF, Gerwe-Wickham K, Greenwell K, Willen KL. (2014). A Rural Pathways Program for High School Students: Reinforcing a Sense of Place. Fam. Med.
DeOnna J. (2008). Rural healthcare manager academy: a best practice in Pennsylvania workforce development. The Pennsylvania nurse.
Freeman VA, Slifkin RT, Patterson PD. (2009). Recruitment and retention in rural and urban EMS: results from a national survey of local EMS directors. Journal of public health management and practice : JPHMP.
Fu MC, Buerba RA, Gruskay J, Grauer JN. (2013). Longitudinal urban-rural discrepancies in the US orthopaedic surgeon workforce. Clinical orthopaedics and related research.
Gifford VM. (2012). Factors that contribute to rural provider retention, service utilization, and engagement in mentorship by cultural experts. Dissertation: Thesis (Ph.D.).
Gossler HE. (2011). Reducing the rural physician shortage in the Pacific Northwest incentivizing rural physicians through financial reimbursement. Dissertation: Thesis (MPA).
Grauer JN, Fu MC. (2013). Editor's spotlight/take 5: longitudinal urban-rural discrepancies in the US orthopaedic surgeon workforce. Interview by Seth S. Leopold. Clinical orthopaedics and related research.
Greenwood JE. (2014). The impact of geography, training, and experience on scope of practice among Certified Registered Nurse Anesthetists. Virginia Commonwealth University.
Hauenstein EJ, Glick DF, Kane C, Kulbok P, Barbero E, Cox K. (2014). A Model to Develop Nurse Leaders for Rural Practice. Journal of Professional Nursing.
Herrmann JA, Hershow RC. (2008). One Medicine, one university: The DVM/MPH program at the University of Illinois. J. Vet. Med. Educ.
Hughes J, Cates JR, Liddon N, Smith JS, Gottlieb SL, Brewer NT. (2009). Disparities in how parents are learning about the human papillomavirus vaccine. Cancer epidemiology, biomarkers & prevention : a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology.
Kruger GJ. (2009). Perceived factors affecting nurse recruitment in northwest Minnesota. University of North Dakota.
Meyer D, Hamel-Lambert J, Tice C, Safran S, Bolon D, Rose-Grippa K. (2005). Recruiting and retaining mental health professionals to rural communities: an interdisciplinary course in Appalachia. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Molanari DL, Jaiswal A, Hollinger-Forrest T. (2011). Rural Nurses: Lifestyle Preferences and Education Perceptions. Online Journal of Rural Nursing & Health Care.
Murray MF, Havener JM, Davis PS, Jastremski C, Twichell ML. (2011). The rural pipeline: building a strong nursing workforce through academic and service partnerships. The Nursing clinics of North America.
Nayar P, Nguyen AT, Apenteng B, Yu F. (2012). Preventable hospitalizations: does rurality or non-physician clinician supply matter?. Journal of community health.
Nelson W, Rosenberg MC, Weiss J, Goodrich M. (2009). New Hampshire critical access hospitals: CEOs' report on ethical challenges. Journal of healthcare management / American College of Healthcare Executives.
Pruthi RS, Neuwahl S, Nielsen ME, Fraher E. (2013). Recent trends in the urology workforce in the United States. Urology.
Rhyne RL, Daniels ZM, Skipper BJ, Sanders ML, VanLeit BJ. (2006). Interdisciplinary health education and career choice in rural and underserved areas. Medical Education.
Skillman SM. (2007). Changes in the rural registered nurse workforce from 1980 to 2004.
Slagle DR. (2010). Rural Versus Urban: Tennessee Health Administratorsâ Strategies on Recruitment and Retention for Allied Health Professionals.
Sullivan D, Rohlfsen L. (2007). Professional Politics and the Challenge of Anesthesia Availability in Rural Hospitals. Inequalities and Disparities in Health Care and Health: Concerns of Patients, Providers and Insurers.
Thaker SI, Pathman DE, Mark BA, Ricketts TC. (2008). Service-linked scholarships, loans, and loan repayment programs for nurses in the Southeast. Journal of Professional Nursing.
Trepanier A, Gagnon MP, Mbemba GI, et al. (2013). Factors associated with intended and effective settlement of nursing students and newly graduated nurses in a rural setting after graduation: a mixed-methods review. International journal of nursing studies.
Wachtel RE, Dexter F. (2012). Training rotations at hospitals as a recruitment tool for Certified Registered Nurse Anesthetists. AANA journal.
Weichel D. (2012). Orthopedic surgery in rural American hospitals: a survey of rural hospital administrators. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.

## SETTING

Publications excluded because they did not report on a healthcare setting or an US healthcare setting.

(2012). Rural Retention Program (RRP) policy framework for health authorities.
Bardella IJ. (2010). Solutions for recruitment and retention of rural and remote health workforce. Family medicine.
Cayley W. (2010). Patients as allies in student education and rural recruitment. Family medicine.
Chen LC. (2010). Striking the right balance: health workforce retention in remote and rural areas. Bull World Health Organ.
Couper ID, Hugo JFM, Conradie H, Mfenyana K. (2007). Influences on the choice of health professionals to practise in rural areas. SAMJ S. Afr. Med. J.
Deirdre J, Florence M, Olive Y. (2012). Putting the (R) Ural in Preceptorship.
Eley D, Young L, Przybeck TR. (2009). Exploring temperament and character traits in medical students; a new approach to increase the rural workforce. Medical teacher.
Eley D, Young L, Przybeck TR. (2009). Exploring the Temperament and Character Traits of Rural and Urban Doctors. Journal of Rural Health.
Haji M, Durairaj V, Zurn P, Stormont L, Mapunda M. (2010). Emerging opportunities for recruiting and retaining a rural health workforce through decentralized health financing systems. Bull World Health Organ.
Igumbor EU, Kwizera EN. (2005). The positive impact of rural medical schools on rural intern choices. Rural and remote health.
Kuhn MKM, Ochsen C. (2009). Demographic and geographic determinants of regional physician supply.
Peach HG. (2011). Rural placement programs. Rural and remote health.
Peake SL, Judd N. (2007). Supporting rural community-based critical care. Curr. Opin. Crit. Care.
Roberts C, Daly M, Kumar K, Perkins D, Richards D, Garne D. (2012). A longitudinal integrated placement and medical students' intentions to practise rurally. Medical education.
Schneider HB. (2008). Attracting medical students to rural areas. CMAJ : Canadian Medical Association journal = journal de l'Association medicale canadienne.
Sen Gupta TK, Hays RB, Kelly G, Buettner PG. (2011). Are medical student results affected by allocation to different sites in a dispersed rural medical school?. Rural and remote health.
Singer J. (2008). Urban and rural health care environments: factors affecting new graduates' choice for employment. Journal of Medical Imaging & Radiation Sciences.
Solowiej K, Upton P, Upton D, et al. (2010). A scheme to support the recruitment and retention of allied health professionals to hard to fill posts in rural areas including commentaries by Kevin O'Toole; Matthew J Leach; Leonie Segal; Ana Manzano-Santaella and Crispin Coombs. International Journal of Therapy & Rehabilitation.
Stone N. (2006). The Rural Interprofessional Education Project (RIPE). Journal of interprofessional care.
Strasser R, Neusy AJ. (2010). Context counts: training health workers in and for rural and remote areas. Bull World Health Organ.
Tolhurst HM, Adams J, Stewart SM. (2006). An exploration of when urban background medical students become interested in rural practice. Rural and remote health.
Vogel L. (2014). Rural premedicine program aims to tackle doctor shortages. journal de l'Association medicale canadienne.
Whalley DSB. (2012). Why do practitioners work in deprived areas? : identifying affinity factors for urban deprived general practice. Dissertation: Thesis (PhD).
Whitelaw AS, Hsu R, Corfield AR, Hearns S. (2006). Establishing a rural Emergency Medical Retrieval Service. Emergency medicine journal : EMJ.
Woloschuk W, Myhre D, Jackson W, McLaughlin K, Wright B. (2014). Comparing the performance in family medicine residencies of graduates from longitudinal integrated clerkships and rotation-based clerkships. Academic medicine : journal of the Association of American Medical Colleges.
Yonge O, Myrick F, Ferguson L. (2011). The Challenge of Evaluation in Rural Preceptorship. Online Journal of Rural Nursing & Health Care.
Ypinazar VA, Margolis SA. (2006). Clinical simulators: applications and implications for rural medical education. Rural and remote health.

## TIMING

Publications excluded due to timing because they exclusively reported on practicing in rural care before 2005.

Backer EL, McLlvain HE, Paulman PM, Ramaekers RC. (2006). The characteristics of successful family physicians in rural Nebraska: A qualitative study of physician interviews. Journal of Rural Health.
Baldwin L, Patanian MM, Larson EH, et al. (2003). Modeling the mental health workforce in Washington State: using state licensing data to examine provider supply in rural and urban areas. Journal of Rural Health.
Brown SR, Birnbaum B. (2005). Student and resident education and rural practice in the Southwest Indian Health Service: a physician survey. Family medicine.
Daniels ZM, Vanleit BJ, Skipper BJ, Sanders ML, Rhyne RL. (2007). Factors in recruiting and retaining health professionals for rural practice. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Doty B, Heneghan S, Gold M, et al. (2006). Is a broadly based surgical residency program more likely to place graduates in rural practice?. World J.Surg.
Evans TC, Wick KH, Brock DM, Schaad DC, Ballweg R. (2006). Academic degrees and clinical practice characteristics: the University of Washington physician assistant program: 1969-2000. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Florence JA, Goodrow B, Wachs J, Grover S, Olive KE. (2007). Rural health professions education at East Tennessee State University: survey of graduates from the first decade of the community partnership program. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Krist AH, Johnson RE, Callahan D, Woolf SH, Marsland D. (2005). Title VII funding and physician practice in rural or low-income areas. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Lang F, Ferguson KP, Bennard B, Zahorik P, Sliger C. (2005). The Appalachian Preceptorship: over two decades of an integrated clinical-classroom experience of rural medicine and Appalachian culture. Academic medicine : journal of the Association of American Medical Colleges.
Miller T, Hooker RS, Mains DA. (2006). Characteristics of osteopathic physicians choosing to practice rural primary care. The Journal of the American Osteopathic Association.
Pacheco M, Weiss D, Vaillant K, et al. (2005). The impact on rural New Mexico of a family medicine residency. Academic medicine : journal of the Association of American Medical Colleges.
Peterson LE, Dodoo M, Bennett KJ, Bazemore A, Phillips RL. (2008). Nonemergency medicine-trained physician coverage in rural emergency departments. The Journal of rural health : official journal of the American Rural Health Association and the National Rural Health Care Association.
Smucny J, Beatty P, Grant W, Dennison T, Wolff LT. (2005). An evaluation of the Rural Medical Education Program of the State University Of New York Upstate Medical University, 1990-2003. Academic medicine : journal of the Association of American Medical Colleges.
Thomas CR, Holzer CE. (2006). The continuing shortage of child and adolescent psychiatrists. Journal of the American Academy of Child and Adolescent Psychiatry.