# APPENDIX 1 SEARCH STRATEGY

## KQ1 RURAL HEALTH PROVIDER NEEDS

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2005-2/11/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel”[Mesh] OR physician*[tiab] OR nurses[tiab] OR nursing[tiab] OR hospitalist*[tiab] OR hospital staff*[tiab] OR healthcare professional*[tiab] OR health care professional*[tiab] OR doctor[tiab] OR doctors[tiab] OR health manpower[mh] OR manpower[tiab] OR workforce OR medical staff, hospital

AND

need[tiab] OR needs[tiab] OR needed[tiab] OR needing[tiab] OR supply[tiab] OR demand[tiab] OR “supply and distribution” [Subheading]

AND

predict* OR projected OR future OR trend*

_______________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

CIN/AHL – 1/1/2005-2/11/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel” OR physician* OR nurses OR nursing OR hospitalist* OR hospital staff* OR healthcare professional* OR health care professional* OR doctor OR doctors OR manpower

AND

need OR needs OR needed OR needing OR supply OR demand

Narrow by SubjectGeographic: - usa

## KQ2 DECISION FACTORS

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2005-2/13/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel”[Mesh] OR physician*[tiab] OR nurses[tiab] OR nursing[tiab] OR hospitalist*[tiab] OR hospital staff*[tiab] OR healthcare professional*[tiab] OR health care professional*[tiab] OR doctor[tiab] OR doctors[tiab] OR health manpower[mh] OR manpower[tiab] OR workforce OR medical staff, hospital

AND

choice* OR choos* OR decision* OR decid*

AND

incentive* OR attract* OR pecuniary OR non-pecuniary OR income OR monetary OR economic* OR financial OR opportunit*) OR influen*

_______________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

CIN/AHL – 1/1/2005-2/13/2015

LANGUAGE:

English

SEARCH STRATEGY #1:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel” OR physician* OR nurses OR nursing OR hospitalist* OR hospital staff* OR healthcare professional* OR health care professional* OR doctor OR doctors OR manpower

AND

choice* OR choos* OR decision* OR decid*

SEARCH STRATEGY #2:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel” OR physician* OR nurses OR nursing OR hospitalist* OR hospital staff* OR healthcare professional* OR health care professional* OR doctor OR doctors OR manpower

AND

incentive* OR attract* OR pecuniary OR non-pecuniary OR income OR monetary OR economic* OR financial OR opportunit* OR incentive*

## KQ3 & 4 RECRUITMENT & RETENTION

DATABASE SEARCHED & TIME PERIOD COVERED:

PubMed – 1/1/2005-2/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel”[Mesh] OR physician*[tiab] OR nurses[tiab] OR nursing[tiab] OR hospitalist*[tiab] OR hospital staff*[tiab] OR healthcare professional*[tiab] OR health care professional*[tiab] OR doctor[tiab] OR doctors[tiab] OR health manpower[mh] OR manpower[tiab] OR workforce OR medical staff, hospital

AND

“Personnel Selection”[Mesh] OR recruit* OR retention OR turnover OR turn over* OR burnout OR burn* out

AND

interven* OR increas* OR program OR programs[tiab] OR programme*[tiab] OR project[tiab] OR projects[tiab] OR telehealth OR telemedicine OR ehealth

_______________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

CIN/AHL – 1/1/2005-2/23/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Health Personnel” OR physician* OR nurses OR nursing OR hospitalist* OR hospital staff* OR healthcare professional* OR health care professional* OR doctor OR doctors OR manpower

AND

recruit* OR retention OR retain* OR personnel selection OR turnover OR turn over* OR burnout OR burn* out

## KQ5 EDUCATION

DATABASE SEARCHED & TIME PERIOD COVERED:

PUBMED - 1/1/2005-2/24/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh]

AND

“Schools, Health Occupations”[Mesh]) OR “Students, Health Occupations”[Mesh] OR internship and residency[mh] OR graduate[tiab] OR post-graduate[tiab] OR postgraduate[tiab] OR college[tiab]

AND

training OR train[ti] OR educat*[tiab] OR medical education OR education, professional

AND

program OR programs[tiab] OR programme*[tiab] OR project[tiab] OR projects[tiab] OR effort[tiab] OR efforts[tiab] OR evaluat*[tiab] OR improv*[tiab] OR success*[tiab] OR efficacy OR survey* OR questionnaire*

_______________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

CIN/AHL – 1/1/2005-2/24/2015

LANGUAGE:

English

SEARCH STRATEGY:

Rural*[tiab] OR agricultur*[tiab] OR wilderness* OR frontier* OR (native AND reservation*) OR farmer OR farmers OR farming OR farm OR farms OR nonurban* OR “non-urban” OR remote*[tiab] OR outback* OR isolated[tiab] OR “small town” OR “small towns” OR village*[tiab] OR settlement* OR “Rural Population”[Mesh] OR “Rural Nursing”[Mesh] OR “Rural Health Services”[Mesh] OR “Rural Health”[Mesh] OR “Hospitals, Rural”[Mesh])

AND

“Health Personnel” OR physician* OR nurses OR nursing OR hospitalist* OR hospital staff* OR healthcare professional* OR health care professional* OR doctor OR doctors OR manpower

AND

training OR train OR trained OR educat* OR graduat* OR post-graduate OR postgraduate OR college

_______________________________________________________________________________________________

DATABASE SEARCHED & TIME PERIOD COVERED:

GREY LITERATURE REPORT – 1/1/2010-1/16/2015

NUMBER OF RESULTS: 76

SEARCH STRATEGY:

Rural