# SUMMARY AND DISCUSSION

Steadily increasing costs of chronic disease care and reports of poor or inconsistent patient adherence with established chronic disease treatment regimens, combined with primary care clinician shortages, provided compelling impetus for exploring whether the use of nurse-managed protocols can increase access and improve chronic disease outcomes in the outpatient setting. In this systematic review, we explored the outcomes of 26 RCTs and 3 non-RCT observational studies with moderate to high quality that assessed the effects of nurse-managed care using disease-specific protocols compared with usual care. Patient populations included those with diabetes, hypertension, hyperlipidemia, and CHF. All studies used an RN or equivalent. There was no report of using an LPN. In these studies, nurse providers had the autonomy to titrate disease medications according to a structured algorithm or protocol. In most studies, nurses also delivered patient education, but other details such as the limits on scope of care and triggers for supervision often were not well described. Additional medication management and behavioral or self-care interventions were commonly part of the intervention. Care was delivered through in-person clinic visits and telemedicine. Study outcomes ranged from health-related quality of life to biophysical and economic outcomes. Findings and overall strength of study evidence are summarized below by KQ.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### KQ 1 Effects of Nurse-Managed Protocols Compared With Usual Care

Studies were divided into two categories: those targeting patients with elevated cardiovascular risk (18 studies) and patients with CHF (10 studies). One additional study was conducted among a cohort of older adults with chronic conditions, which included a mixture of elevated cardiovascular risk and CHF. The majority of patients receiving nurse-managed protocol care had moderate disease (i.e., moderate hypertension or CHF).

The most robust finding is that nurse-managed protocols had a positive impact on the biophysical outcomes of chronically ill patients. Among the studies targeting elevated cardiovascular risk, HbA1c improved by approximately 0.4 percentage points (moderate strength of evidence [SOE]); systolic and diastolic blood pressure improved by 4 mmHg and 2 mmHg, respectively (moderate SOE); total cholesterol improved by 9 mmol/l, and LDL improved by 12 mmol/l (low SOE). Among the CHF studies, nurse-managed care resulted in a significant decrease in mortality and fewer CHF-related hospitalizations (high SOE). For both patient groups, nurse-managed protocols also were more likely to achieve target goals for markers of disease severity (e.g., lipid values) or medication-prescribing goals (moderate SOE).

Subgroup analyses showed some differences between in-person and telephone-based care studies, non-U.S. and U.S.-based studies, and among studies that incorporated self-management plans or specific behavioral interventions. Interventions delivered primarily by telephone showed significantly greater effects for total and LDL cholesterol in patients with elevated cardiovascular risk and greater mortality reductions in patients with CHF. There was a similar pattern for other outcomes but these were not statistically significant. These exploratory analyses suggest that telephone-based care may be a promising delivery mode for implementing nurse-managed protocols. Other subgroup analyses did not show any consistent pattern across outcomes.

Patient treatment adherence was reported in 6 studies, and medication adherence was reported in only 1. Effects of nurse-managed protocols on lifestyle changes and medication adherence were reported infrequently, but when reported showed an overall pattern of small positive effects (low SOE). The strength of evidence was insufficient to estimate a treatment effect for all other outcomes: nurse satisfaction, health-related quality of life, and health care costs. Table 6 summarizes the strength of evidence for KQ 1.

Table 6 Detailed summary of the strength of evidence for KQ 1

Outcome | Strength of Evidence Domains | | | | Effect Estimate (95% CI) | SOE
Outcome | Number of Studies (Patients) | Study Design/Risk of Bias | Consistency Directness | Precision Publication Bias | Effect Estimate (95% CI) | SOE
Nurse-managed protocol intervention vs. usual care - cardiovascular risk studies
Hemoblogin A1c | 8 (2633) | RCT/Moderate | Inconsistent Direct | Precise None detected | MD = -0.40 (-0.63 to -0.17) | Moderate
Systolic blood pressure | 12 (10,224) | RCT/Moderate | Inconsistent Direct | Precise Possible bias | MD = -3.68 (-5.67 to -1.69) | Moderate
Diastolic blood pressure | 12 (10,224) | RCT/Moderate | Inconsistent Direct | Precise None detected | MD = -1.56 (-2.57 to -0.55) | Moderate
Blood pressure at goal | 10 (9707) | RCT/Moderate | Inconsistent Direct | Precise None detected | OR = 1.41 (1.12 to 1.78) RD = 77 more per 1000 patients (24 to 133 more) | Moderate
Total cholesterol | 9 (3494) | RCT/Moderate | Inconsistent Direct | Imprecise None detected | MD = -9.37 (-17.87 to -0.87) | Low
LDL cholesterol | 6 (1119) | RCT/Moderate | Inconsistent Direct | Imprecise None detected | MD = -12.07 (-24.10 to -0.03) | Low
Cholesterol at goal | 11 (9221) | RCT/Moderate | Inconsistent Direct | Precise None detected | OR = 1.54 (1.14 to 2.08) RD = 106 more per 1000 patients (33 to 174 more) | Moderate
Nurse-managed protocol intervention vs. usual care–congestive heart failure studies
Mortality | 10 (2836) | RCT/Low | Inconsistent Direct | Precise None detected | OR=0.71 (0.52 to 0.96) RD=36 fewer per 1000 patients (5 to 62 fewer) | Moderate
Total hospitalizations | 6 (2352) | RCT/Low | Inconsistent Direct | Imprecise None detected | OR=0.83 (0.62 to 1.10) No significant difference: RD = 32 fewer per 1000 patients (76 fewer to 18 more) | Low
CHF-related hospitalizations | 5 (2231) | RCT/Low | Consistent Direct | Precise None detected | OR=0.62 (0.49 to 0.80) RD=42 fewer per 1000 patients (22 to 57 fewer) | High
ACE/ARB prescribed | 6 (2050) | RCT/Low | Consistent Direct | Imprecise None detected | OR=1.15 (0.90 to 1.46) No significant difference: RD = 18 more per 1000 patients (15 fewer to 45 more) | Moderate

Abbreviations: ACE=angiotensin-converting enzyme inhibitor; ARB=angiotensin receptor blocker; CHF=congestive heart failure; CI=confidence interval; LDL=low-density lipoprotein; MD=mean difference; OR=odds ratio; RCT=randomized controlled trial; RD=risk difference; RR=risk ratio; SOE=strength of evidence

### KQ 2 Adherence to Nurse-Managed Protocols

No studies reported fidelity to important elements of the treatment protocol. Indirect evidence (e.g., proportion of patients prescribed the indicated medication) suggests reasonable adherence to the medication elements of the protocol. Few studies (only 2) reported the type and amount of treatment protocol adherence. Though these studies demonstrated nurse protocol adherence by nurses in intervention groups compared with controls, the strength of evidence on adherence was judged to be insufficient.

### KQ 3 Adverse Effects Associated With Nurse-Managed Protocols

The absence of reports of adverse effects in the studies is notable. Only 3 (10%) of the 29 included studies reported adverse effects. In the one, adverse effects occurred at similar rates in both diabetes intervention and control groups. Given the minimal number of studies citing increases in adverse effects, the strength of evidence was judged to be insufficient to determine the impact of nurse-managed protocols on adverse effects in chronic disease treatment studies.

## CLINICAL AND POLICY IMPLICATIONS

In 2010 the Veterans Health Administration began to implement the Patient Aligned Care Team, known as PACT. The goal of this initiative was to transform the VA health care delivery system to one that is increasingly patient-centered. PACTs focus on each Veteran working together with a team of health care professionals, family members, and caregivers to plan for whole-person care and wellness. The PACT model serves as an example of how a team-based approach can be used to improve the quality and efficiency of chronic disease care. Because effective management of chronic diseases can be time-intensive, costly, and involve both medical therapy and behavioral and self-management interventions, it is becoming increasingly important to involve a multidisciplinary team such as PACT. Coupled with the 2010 Patient Protection and Affordable Care Act—which is expected to generate an influx of patients into the U.S. health system—there is increasing demand for chronic illness care. Further, with an expanding U.S. population, the number of patients per physician is growing. As the largest segment of the health care workforce, nurses are ideally suited to collaborate with other professionals in meeting the increasing demand for chronic disease care. Nurses often work in interdisciplinary teams and oversee the integration of care by multiple providers, in addition to providing active oversight of patients' abilities to understand and comply with complex medical regimens.77

Systematic reviews and meta-analyses led by Clark et al.32,33 found that nurse-led interventions have been shown to improve control of high blood pressure in people with diabetes (-5.8 mmHg),33 and showed reductions in systolic blood pressure (-8.2 mmHg).32 Further, results showed improved blood pressure in studies where the nurse used an algorithm to deliver care (-8.9 mmHg).32 A Cochrane review indicated similar results.37 Nurse-managed interventions by a heart failure specialist nurse reduced CHF-related readmissions after 12 months of followup and reduced all-cause readmission and all-cause mortality. While results from this meta-analysis and systematic review are consistent with prior literature, this review examined nurse-led interventions across multiple chronic illnesses and required the nurse to have the autonomy to titrate medication.

Our systematic review and meta-analysis suggest nurse-managed care using an RN with defined protocols and physician supervision to titrate medications may be promising for improving health outcomes among patients with chronic disease conditions. The finding that nurse-managed protocols have been implemented and evaluated in a variety of chronic conditions suggests that such interventions have an overall positive effect on health outcomes in patients with elevated cardiovascular risk. There is also preliminary evidence of a decrease in mortality and resource utilization in patients with CHF.

However, these results leave many questions unanswered. Clinical replication of these nurse-managed interventions would be difficult at this time. Protocols used were often incompletely described and often failed to report adherence to the protocol by the nurse and the extent to which the nurse actually utilized autonomy to titrate or prescribe medications. In some studies, telephone followup augmented clinic encounters. Few studies reported the mean number of contacts, and many did not explain the planned number of nursing contacts. While this lack is not uncommon,78 it makes replication challenging. In addition, while all studies in this review required the nurse to have the autonomy to titrate medications, they did not all allow the nurse to prescribe new medications.

More detailed information is needed about the practice boundaries, training experience required, clinical knowledge needed, decisionmaking confidence, communication capacity, the best patient population to target, and supervision needed for safe and effective clinical care. Some of the studies used very experienced nurses with special certifications (e.g., diabetes-certified nurse). In the United Kingdom, nurses in a variety of positions are involved in the management of medication for patients with diabetes. Findings from a UK survey revealed that among 214 nurses with prescribing rights, more than 85 percent had undertaken specialist training in diabetes and had a wealth of clinical experience.79 It is important to note that there was no evidence examining the role and implications of the LPN using nurse-managed protocols. Thus, we cannot make recommendations at this time on the use of LPNs in this expanded role. Also, studies overall targeted patients with mild to moderate symptom severity. Thus, complex or unstable patients may not be best suited for these kinds of nurse-managed interventions. Last, there were limited data on the impact of nurse-managed protocols on health-related quality of life; further research is needed.

Review results were also promising with regard to improving quality measures. However, we know little about the acceptability to patients and primary care providers as well as to members of the nursing staff. We do not know if patients prefer this novel, nurse-led model of care over the traditional disease management approach where the physician remains largely in charge and the nurse is assigned to give adjunctive care. Further, we do not know if the nurse would prefer this expanded scope of practice or what percentage of RNs without advanced practice credentials would be willing to accept this expanded role.

Nurse-managed protocols expand the legal scope of practice of the RN. The practice of nursing includes comprehensive assessments of physical, mental, and social aspects of human conditions. Nursing responsibilities may include physical exams, health histories, patient education and counseling, and coordination of care.80 Nurses implement treatments and pharmacological interventions by persons authorized by state regulations. RNs delegate and supervise nursing care of non-RNs, which include LPNs.

A clinical nurse specialist (CNS) is an advanced practice registered nurse who has a master's degree in nursing and provides direct patient care. The scope of practice is based on the course of study completed. The primary focus of the CNS is improvement in patient outcomes and nursing care. The role also includes responsibilities for diagnosis and treatment of disease, and health promotion and prevention in individuals, families, and communities. However, the CNS does not diagnose and manage disease, prescribe medications, interpret or order laboratory tests, or make referrals. This is the role of the certified nurse practitioner.81

In many countries such as in the United Sates, the nursing scope of practice is regulated by a governing body such as a board of nursing. Therefore, before a general policy recommendation can be made in an existing health system, it would be prudent to ensure that the scope of expansion is in concert with the nursing scope of practice endorsed by the governing body.

If nurse-managed protocols were to be implemented in a health care system such as the VA, careful selection, training, and supervision of those nurses would be required. Detailed evidence-based protocols would need to be developed with specifics on the level of training, experience, and competency needed of the RN to be given autonomy to titrate medications. The protocol would also need to specify the targeted acuity of the patients, specific medications and scope of titration, and rules on reporting adverse events and patients status updates to a supervisor. A nurse-managed protocol would need to be piloted in selected clinics where a physician would choose to champion this new model of care and agree to supervise this expanded RN role. Also, because RNs have differing educational backgrounds and roles in the VA setting, a “phased-in” approach would be recommended, where nurse-managed protocols are tested first with experienced and even certified RNs.

Finally, we will need to think carefully about the role of physicians, nurse practitioners, physician assistants, and nurses in patient-centered medical home models of care. Specifically, if nurses are to assume an expanded role, will this eliminate nurses in the team with a traditional role? It is clear that we need to work in teams, but the proper role and skills or training needed for each profession must be fine-tuned. While assigning only the most complex patients to a physician and only the moderate or “less” sick patients to a nurse or advanced practice provider is possible, a balanced approach to responsibilities will be important to maintain staff satisfaction and prevent burnout—and to prevent confusion among patients and consumers on provider roles.82

## STRENGTHS AND LIMITATIONS

Our study has a number of strengths, including a protocol-driven review, a comprehensive search, a careful quality assessment, and rigorous quantitative synthesis methods. Our report, and the literature, also has limitations. An important limitation is the lack of detailed description of the interventions and, in particular, the protocols the nurses used. There was limited reporting of the intensity of the intervention, treatment adherence by patients, protocol adherence by nurses, health-related quality of life, and resource utilization. Other performance measures of interest such as micro-albumin levels were rarely reported, and nursing staff satisfaction with the protocols was not reported. There also was limited reporting of the educational level and supervision required of the nurses. Studies were limited to the use of an RN, and there was no report of using LPNs. Finally, the outcomes reported varied across studies and contributed to unexplained variability.

## RECOMMENDATIONS FOR FUTURE RESEARCH

We used the framework recommended by Robinson et al.83 to identify gaps in evidence and classify why these gaps exist (Table 7). This approach considers PICOTS (population, intervention, comparator, outcomes, timing, and setting) to identify gaps and classifies them as due to (1) insufficient or imprecise information, (2) biased information, (3) inconsistency or unknown consistency, and (4) not the right information. VA and other health care systems should consider their clinical and policy needs when deciding whether to invest in research to address gaps in evidence.

Table 7 Evidence gaps and future research

Evidence Gap | Reason | Type of Studies to Consider
Patients
Effects in patients with complex disease or multiple chronic conditions | Insufficient information | Single and multisite RCTs Quasi-experimental studies
Interventions
Uncertainty about effects of narrowly focused (e.g., blood pressure) or multitarget (e.g., HbA1c, blood pressure, and lipids) interventions | Insufficient information Exploratory analysis suggests possible differential effect | RCTs or quasi-experimental studies of focused versus multi-target interventions
Interventions described in sufficient detail for replication | Insufficient information | Qualitative evaluation of nurse-managed protocols to address implementation needs of stakeholders
Uncertain level of training and supervision needed | Insufficient information | Job-skills analysis Survey of authors and nurse who have evaluated nurse-managed protocols
Outcomes
Uncertain effects on patient and staff satisfaction and experience | Insufficient information | Nonrandomized or cluster randomized, multisite implementation studies, qualitative studies
Uncertain effects on adverse events | Insufficient information | Multisite observational studies
Uncertain effects on health system costs | Insufficient information | Costs analyses, particularly in patient group with elevated CV risk
Fidelity to the intervention protocol | Insufficient information | Quantitative and qualitative approaches as part of RCT or non-RCT trials or implementation studies
Uncertain whether there would be unintended consequences to other aspects of the health care system if nurse-managed protocols were implemented | Insufficient information | Multisite observational studies

Abbreviation: HbA1c=glycosylated hemoglobin; RCT = randomized controlled trial

Our review shows that nurse-managed protocols help to improve health outcomes among patients with moderate severity of diabetes, hypertension, hyperlipidemia, and CHF.

Studies overall targeted patients with mild to moderate symptom severity. Thus, further research is needed to understand the effects of nurse-managed protocols in complex or unstable patients.

To help guide the development and implementation of nurse-managed protocols, we recommend an exemplar VA quality improvement study conducted by Watts and colleagues (2011)28 that provides detailed protocol descriptions but was not included in this report as it did not meet the Cochrane EPOC Guidelines for study designs. This project involved an internal training program for nurse case managers to improve glycemic outcomes for patients in the Cleveland Veterans Administration health care system. Existing nursing staff members were trained through weekly sessions to assume the role of a nurse case manager and encouraged to become certified diabetes educators. Nurses assumed the case management of patients with uncontrolled glycemic levels (HbA1c ≥9%). By following a detailed protocol, nurses were given authority to make referrals and to titrate insulin as prescribed by a primary care provider. Results indicated that, compared with usual care, nurse case managers achieved meaningful improvement in glycemic level control.

## CONCLUSIONS

There is a pressing need to improve the medical management of adults with chronic disease, and our findings from this review of 29 studies justify testing nurse-managed protocols in the VA where detailed intervention components are monitored and data are collected. While there are many patient-level barriers that impede optimal treatment outcomes, the shortage of primary care clinicians in outpatient settings provides compelling justification to develop and test new models of chronic disease care. With the implementation of PACTs, the VA will play a critical role in reconfiguring team-based care models to expand the responsibilities of team members such as RNs to practice to the full extent of their education and training in order to improve outcomes for patients with chronic diseases.

As the largest health care workforce group, nurses are in an ideal position to collaborate with other team members in the delivery of more accessible and effective chronic disease medical care. Results from this systematic review and meta-analysis suggest that nurse-managed protocols have positive effects on the outpatient management of adults with stable, common chronic conditions such as type 2 diabetes, hypertension, hyperlipidemia, and CHF.