# RESULTS

## LITERATURE SEARCH

The flow of articles through the literature search and screening process is illustrated in Figure 2. Our search identified 2650 unique citations from a combined search of MEDLINE via PubMed (n=1844), CINAHL (n=388), Embase (n=360), and the Cochrane Central Database (n=58). Manual searching of included study bibliographies and review articles added 35 more citations. Another article missed in our search28 was identified by a reviewer, for a total of 2686 unique citations. After applying inclusion and exclusion criteria at the title-and-abstract level, 340 full-text articles were retrieved and screened. Of these, 309 were excluded at the full-text screening stage, leaving 31 articles (represented by 29 unique studies plus 2 companion articles) for data abstraction. Note that four studies were excluded because we could not verify whether nurses had the authority to initiate or titrate medications and there was no response to our author query for clarification.45-48 Of the 29 unique studies, 26 are RCTs and 3 are non-RCTs.

Figure 2 Literature flow diagram

^a^ Refer to Glossary for a definition of companion articles.

## DESCRIPTION OF INCLUDED STUDIES

We identified 29 studies that met our inclusion criteria.43,49-76 Of these, 18 focused on management of patients with elevated cardiovascular risk (diabetes mellitus, hypertension, or hyperlipidemia), 43,49,51-53,56,57,60,62,63,65,67-72,76 10 focused on management of patients with congestive heart failure (CHF),50,54,55,59,61,64,66,73-75 and 1 focused on resource utilization of older adults with chronic conditions.58 Detailed study characteristics for each of the 29 studies are in Appendix F.

Twenty-six studies were RCTs; among the remaining three, two were controlled before-and-after studies67,71 and one was a nonrandomized controlled clinical trial.58 Of these, two focused on diabetes and one on older adults. The comparator was usual care in all but one study, which used a reverse-control design where each intervention served as the control for the other. Eighteen of these studies were conducted in Western Europe and 11 in the United States; none were reported to be conducted in military or VA settings.

All 29 studies required the nurse to have the autonomy to titrate medications; however, only 20 reported that the nurse was allowed to independently initiate a new medication. All 29 studies used a protocol to guide the nurses, but only 23 provided the actual algorithm or a citation to it; 6 studies did not.50,57,58,64,66,72 For most studies, the protocol was limited to an algorithm describing medication titration. Only one study explicitly described the scope of practice and interactions with the team physician. All studies used an RN or equivalent as the interventionist; no studies reported the use of LPNs. For studies conducted outside the United States, authors who were queried about the type of nurse used indicated that they most closely resembled the U.S. equivalent of an RN. Next, we give further details and analysis of the included studies organized by KQ.

## KEY QUESTION 1 For adults with chronic medical conditions, do nurse-managed protocols compared with usual care improve the following outcomes?

- Nursing staff satisfaction
- Treatment adherence
- Quality measures
- Resource utilization

### Key Points

- For patients with elevated cardiovascular risk, nurse-managed protocols:
  ○ Had an overall positive effect on improving HbA1c, blood pressure, and hyperlipidemia, but intervention effects varied substantially across studies.
  ○ Were associated with more patients reaching target goals in total cholesterol and blood pressure compared with usual care.
- For patients with CHF, nurse-managed protocols were associated with:
  ○ Lower all-cause mortality
  ○ More patients being prescribed an angiotensin-converting enzyme inhibitor or angiotensin receptor blocking (ACE/ARB) agent
  ○ Decreased CHF-related hospitalizations compared with usual care
- Effects on nursing staff satisfaction were not reported.
- Effects on treatment adherence were reported infrequently but showed a pattern of improved adherence to lifestyle goals.
- The educational preparation needed to assume this expanded nurse role was not well reported.

### Studies Targeting Elevated Cardiovascular Risk: Diabetes, Hypertension, Hyperlipidemia

Eighteen studies targeted patients with elevated cardiovascular risk.43,49,51-53,56,57,60,62,63,65,67-72,76 Table 4 summarizes the study and patient characteristics. A nurse-led clinic was used to deliver the interventions in 14 of these studies.49,51-53,57,62,63,65,67-71,76 Supervision of the nurse was almost exclusively by a physician, and half the studies reported this as specifically a primary care physician. All nurse interventionists were RNs or equivalent and did not meet the threshold of advanced practice nursing. Of the studies that reported the nurses' training, 3 studies used specialists (e.g., diabetes-certified), 10 reported study-specific training, and 1 used nurse case managers.

Table 4 Study and patient characteristics of included diabetes, hypertension, and hyperlipidemia studies^a^

Study Characteristics | Cardiovascular Risk Studies
N studies (N patients) | 18 studies (23,004 patients)^b^
Study design: N studies (%)
RCT | 16 (89%)
Non-RCT | 2 (11%)
Setting: N studies (%)
General medical | 12 (67%)
Medical specialty | 3 (17%)
Primary clinic and specialty | 2 (11%)
Telephone- and clinic-delivered care | 1 (5.5%)
Intervention target: N studies (%)
Glucose | 12 (67%)
Blood pressure | 15 (83%)
Lipids | 14 (78%)
Intervention delivery: N studies (%)
Clinic visits | 15 (83%)
Primarily telephone | 3 (17%)
Balance of visits and telephone | –
Nurse training: N studies (%)
Specialist (i.e., clinical certification or diabetes nurse educator) | 3 (17%)
Received study-specific training | 10 (55%)
Case manager | 1 (5.5%)
Not described | 4 (22%)
Medication initiation: N studies (%) | 12 (67%)
Education or behavioral strategies: N studies (%)
Education | 16 (89%)
Specific behavioral strategy (e.g., motivational interviewing) | 3 (17%)
Self-management plan | 9 (50%)
Risk of bias: N studies (%)
Low | 4 (22%)
Moderate | 12 (67%)
High | 2 (11%)
Patient characteristics
Age: median (range) | 58.3 (34.7 to 72.1)^c^
Sex: N patients (%)^d^
Female | 4126 (47%)
Male | 4716 (53%)
Race: N patients (%)
Black | 52 (0.2%)
Hispanic | 653 (2.8%)
White | 2280 (9.9%)
Other | 636 (2.8%)
Not reported | 19,383 (84.3%)^e^
Disease severity: median (range)
HbA1c (%) | 8.1 (8.0 to 8.2), NR=16
SBP (mm Hg) | 149.4 (119 to 161.3), NR=4
DBP (mm Hg) | 80 (69 to 87.7), NR=4
LDL (mg/dl) | 124.9 (85.3 to 131.5), NR=10

a Excluded from this table is one study58 conducted in older adults with complex conditions that included diabetes, hypertension, and congestive heart failure.

b Number of participants represents the grand mean of 22,839 and 23,170 because one included study68 randomized such that hypertension and hyperlipidemia results were reported on two different but overlapping populations.

c Age represents 16 of the 18 studies because two studies53,68 did not report age or reported it as a categorical variable.

d Sex represents 17 of the 18 studies because one study68 did not report the sex distribution of their populations.

e Race represents the grand mean of 19,218 and 19,549 because one study68 reported on an overlapping sample.

Abbreviations: DBP=diastolic blood pressure; HbA1c=glycosylated hemoglobin; LDL=low-density lipoprotein; SBP=systolic blood pressure

Additional intervention was delivered by the nurse in 16 of the 18 studies and included education, behavioral (i.e., motivational interviewing), or self-management. In 12 studies, the intervention was exclusively clinic-delivered, and in 4 studies either exclusively telephone-delivered or a combination of telephone- and clinic-delivered. The other two studies did not report additional intervention beyond medication titration.52,63 Outcomes were assessed at 6 to 36 months, with most studies reporting outcomes at 12 months or longer.

Overall, baseline characteristics showed that patients with diabetes had elevated HbA1c of approximately 8.0 percent or more, most patients with hypertension had stage 1 or moderate hypertension, and patients with hyperlipidemia had borderline high to near ideal lipid levels.

We assessed the risk of bias for each study and found that 2 studies had high risk of bias,57,71 12 had moderate risk,43,49,51,52,56,63,65,67-70,76 and 4 had low risk.53,60,62,72 A rating of moderate risk was largely due to possible contamination from a concurrent intervention, outcome assessors not blinded, or incomplete outcome data. In the study with high risk of bias, there was inadequate randomization. Overall, there was moderate risk of bias in these studies.

#### Nursing Staff Satisfaction

None of the included studies reported on nursing staff satisfaction.

#### Treatment Adherence

Treatment adherence was reported in five studies, of which four were RCTs. Behavior adherence was reported in four adherence was reported in four,49,56,65,67 and medication adherence was reported in one.72 Reported outcomes on behavioral adherence varied. Three studies reported effects on smoking, two of those showing small, nonstatistically significant decreases in the intervention groups (risk difference <2%),65,67 and one showing a 9-percent reduction in smoking compared with the control group (p=.05).49

Effects on physical activity were reported in three studies,49,56,67 all showing increased physical activity or exercise capacity. Meulepas et al.,67 found a MD of 0.4 improvement on a 5-point Likert scale (95% CI, 0.03 to 0.8). Allison et al.,49 reported an increase in minutes of exercise per week (183 ± 118) compared with control (127 ± 107, p<0.01) and Debusk et al.56 reported increased functional capacity measured at 6 months (MD 9.3; 95% CI, 9.0 to 9.6) compared with usual care (MD 8.4; 95% CI, 8.1 to 8.7). Allison et al.49 reported no significant differences between the intervention and control on diet, but weight (kilograms) decreased more in the intervention group (-0.3 ± 4.9) compared with control (+1.7 ± 5.0, p=0.03). Debusk et al.56 found that among the intervention group the proportion of participants consuming a diet very low in cholesterol and saturated fat increased from 31 percent at baseline to 88 percent at 90 days (p<0.001).

Among the study that reported treatment adherence to medication, Rudd, et al.72 reported higher medication adherence in the intervention group compared with control (p=0.03). The intervention groups' rate of daily adherence during the 6-month study period was 80.5 percent ± 23.0 percent, versus 69.2 percent ± 31.1 percent in the usual care group. In summary, effects of nurse-managed protocols on indicated lifestyle changes and medication adherence were reported infrequently, but when reported show an overall pattern of small positive effects.

#### Quality Measures

##### Biophysical Markers

Hemoglobin A1c (HbA1c). Of the 15 studies conducted in patients with diabetes, 10 studies involving 2633 patients targeted glucose control. Figure 3 shows the forest plot of the random-effects meta-analysis of nurse-managed protocols on hemoglobin A1c (HbA1c) stratified by RCT versus non-RCT. Nurse-managed protocols were associated with lower HbA1c compared with usual care in the RCTs (MD -0.40; 95% CI, -0.63 to -0.17) with effects varying significantly (Q=23.19, degrees of freedom [df]=7, p=0.002; I^2^=70%).

Figure 3 Effects of nurse-managed protocols on hemoglobin A1c

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; SD=standard deviation

We performed subgroup analyses comparing studies conducted in the United States versus other countries, studies targeting HbA1c alone versus multiple conditions, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. These analyses showed greater effects for studies conducted in the United States (-0.92 vs. -0.23, p=0.0003) and for studies targeting only HbA1c (-1.1 vs. -0.31, p=0.005); treatment variability was reduced in these subgroups. No studies that targeted glucose control used telephone-based care. Thus, nurse-managed protocols were associated with a mean decrease in HbA1c, but effects varied markedly. Exploratory subgroup analysis suggests some of the variability in intervention effects may be explained by country and by the specificity of the intervention (Appendix G).

Effects of nurse-managed protocols on HbA1c from the non-RCTs were in the same direction (MD -1.12; 95% CI, -2.99 to 0.74) yet with higher variability and effects varying widely (Q=33.86, df=1, p<0.001; I^2^=97%). Both non-RCTs67,71 found statistically significant reductions in HbA1c from baseline to followup among patients participating in a nurse-managed protocol.

Systolic and diastolic blood pressure (SBP, DBP). Of the 18 studies conducted in patients with elevated cardiovascular risk, 14 targeted blood pressure control. Twelve RCTs (10,224 patients) and one non-RCT (885 patients) were included in the quantitative analyses. Compared with usual care, nurse-managed protocols were associated with lower SBP (Figure 4) and DBP (Figure 5).

Figure 4 Effects of nurse-managed protocols on SBP

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; SD=standard deviation

Figure 5 Effects of nurse-managed protocols on DBP

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; SD=standard deviation

In analyses restricted to RCTs, the intervention was associated with lower SBP (MD -3.68; 95% CI, -5.67 to -1.69) and DBP (MD -1.56; 95% CI, -2.57 to 0.55). For both outcomes, intervention effects varied significantly. Because of variability in effects between studies, we conducted a sensitivity analysis to evaluate this variability. We excluded the studies by Bebb et al.52 and New et al.,68 which involved training nurses to implement nurse-managed protocols but not in directly delivering the intervention. Without these studies, intervention effects were only slightly stronger (SBP MD 5.1; 95% CI, -7.70 to -2.51; DBP MD -1.64; 95% CI, -2.76 to -0.52), but variability in intervention effects remained high (I^2^≥67%). Funnel plots, interpreted visually, suggest possible publication bias when examining effects on SBP but not for DBP (Appendix B).

Effects of nurse-managed protocols on SBP and DBP from the one non-RCT67 were in the same direction, with nonstatistically significant reductions in SBP from baseline to followup among patients participating in a nurse-managed protocol. Due to only one non-RCT, a test of heterogeneity was not possible. Thus overall, nurse-managed protocols were associated with a mean decrease in SBP and DBP.

We performed subgroup analyses to explore for differences in intervention effects between studies conducted in the United States versus other countries, studies targeting BP alone versus multiple conditions, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. There were no statistically significant differences in treatment effects for any of these subgroup analyses (Appendix G).

Total cholesterol and low-density lipoprotein (LDL) cholesterol. Of the 18 studies conducted in patients with elevated cardiovascular risk, 14 targeted hyperlipidemia. Nine RCTs (3494 patients) and two non-RCTs (1114 patients) were included in the quantitative analyses. Compared with usual care, nurse-managed protocols were associated with lower total cholesterol (Figure 6) and lower LDL cholesterol (Figure 7). Overall, fewer studies reported LDL than total cholesterol.

Figure 6 Effects of nurse-managed protocols on total cholesterol

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; SD=standard deviation

Figure 7 Effects of nurse-managed protocols on LDL cholesterol

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; SD=standard deviation

In analyses restricted to RCTs, the intervention was associated with lower total cholesterol (MD -9.37; 95% CI, -17.87 to 0.87) and LDL cholesterol (MD -12.07; 95% CI, -24.10 to -0.03) with marked variability in intervention effects (I^2^≥ 89%). We conducted subgroup analyses comparing studies conducted in the United States versus other countries, studies targeting hyperlipidemia alone versus multiple conditions, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. These analyses showed greater effects for studies that were telephone-based compared with in-person care in total cholesterol (-24.33 vs. -7.17, p=0.0008) and LDL cholesterol (-24.7 vs. -9.22, p=0.03). Treatment variability was reduced in these subgroups. Exploratory subgroup analysis suggests some of the variability in intervention effects may be explained by mode of delivery (Appendix G).

Effects of nurse-managed protocols on total cholesterol and LDL cholesterol from the two non-RCTs67,71 were in the same direction, with nonstatistically significant reductions in total cholesterol. However, there was a statistically significant reduction (MD -25.90; 95% CI, -42.41 to -9.39) in LDL cholesterol in one non-RCT71 from baseline to followup among patients participating in a nurse-managed protocol. Due to only one non-RCT assessing LDL cholesterol, a test of heterogeneity was not possible. Thus overall, nurse-managed protocols were associated with a mean decrease in total cholesterol and LDL cholesterol.

##### Process-of-care measures

Target blood pressure values. Of the 18 studies conducted in patients with elevated cardiovascular risk, 11 focused on achieving target blood pressure values. Figure 8 shows the forest plot of the random-effects meta-analysis of nurse-managed protocols on the process measure of achieving target total cholesterol values stratified by RCT and non-RCT. Ten RCTs (9707 patients) and 1 non-RCT (885 patients) were included in the quantitative analysis. Some studies did not report this performance metric but did report change in blood pressure.70-72 One study reported effects on SBP and DBP but, as a diabetes-focused study, had no expectations of effects on blood pressure.51 These were excluded from this analysis. It is important to note that target blood pressure goals may have varied by study.

Figure 8 Effects of nurse-managed protocols on achieving target blood pressure values

Abbreviations: CI=confidence interval; RCT=randomized controlled trial

Nurse-managed protocols were significantly more likely to achieve target blood pressure values compared with controls (OR 1.41; 95% CI, 1.12 to 1.78), with high variability in treatment effects (Q=35.20, df=9, p<0.001; I^2^=74%). Because of variability in effects between studies, we conducted a sensitivity analysis to evaluate this variability. We excluded two studies52,68 that trained practices to implement nurse-managed protocols rather than delivering the intervention directly. Without this study, effects were slightly larger (OR 1.69; 95% CI, 1.18 to 2.43), and variability in treatment effects remained high (I^2^=72%). We performed subgroup analyses to explore for differences in intervention effects between studies conducted in the United States versus other countries, studies assessing target blood pressure values alone versus multiple process-of-care measures, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. There were no telephone-based studies and no statistically significant differences in treatment effects for any of the other subgroup analyses (Appendix G).

Using the summary odds ratio (OR) and median event rate from the control arm of the trials, though not statistically significant, we estimated the absolute treatment effect as a risk difference of 77 more achieved target total blood pressure values per 1000 patients (95% CI, 24 to 133 more). Funnel plots suggested some asymmetry but likely no clear indication of publication bias (Appendix B).

In the one non-RCT,67 nurse-managed protocols were associated with a nonstatistically significant increase on achieving target blood pressure values (OR 1.08; 95% CI, 0.83 to -1.41).

Target total cholesterol values. Of the 18 studies conducted in patients with elevated cardiovascular risk, 11 targeted total cholesterol target values. Figure 9 shows the forest plot of the random-effects meta-analysis of nurse-managed protocols on the process measure of achieving target total cholesterol values. Eleven RCTs with 9221 patients were included in the quantitative analysis. Nurse-managed protocols were significantly more likely to achieve target total cholesterol values compared with controls (OR 1.54; 95% CI, 1.14 to 2.08), with moderate variability in treatment effects (Q=71.59, df=10, p<0.001; I^2^=56%). Because of variability in effects between studies, we conducted a sensitivity analysis to evaluate this variability. We excluded one study,68 which trained nurses to implement nurse-managed protocols, rather than delivering the intervention directly. Without this study, effects were slightly larger (OR 1.64; 95% CI, 1.11 to 2.41).

Figure 9 Effects of nurse-managed protocols on achieving target total cholesterol values

Abbreviations: CI=confidence interval; RCT=randomized controlled trial; SD=standard deviation

Using the summary OR and median event rate from the control arm of the RCTs, we estimated the absolute treatment effect as a risk difference of 106 more achieved target total cholesterol values per 1000 patients (95% CI, 33 to 174 more). It is important to note that target cholesterol goals may have varied by study. Funnel plots did not suggest publication bias (Appendix B).

We performed subgroup analyses to explore for differences in intervention effects between studies conducted in the United States versus other countries, studies assessing target total cholesterol values alone versus multiple process-of-care measures, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. There were no statistically significant differences in treatment effects for any of these subgroup analyses (Appendix G).

Other performance measures. Other performance measures of interest were rarely reported. Achieving target urine microalbumin-to-creatinine ratio was reported to reach 100 percent in nurse-managed protocols in one controlled before and after study.71 The same study reported 100 percent of patients achieved foot exam goals and 81 percent of patients achieved eye exam goals, and a second study using a similar design by Meulepas and colleagues67 reported a nonsignificant increase in intervention patients achieving the outcome goals of eye exams (p=0.1) and foot exams (p=0.2) compared with control. Reduction in the proportion of patients with very poor glycemic control (A1c ≥8.5) was achieved in half the patients in one study (OR 1.69; 95% CI, 1.25 to 2.29).67

#### Resource Utilization

##### Total costs

Reporting of resource utilization was limited and noted in only three studies.60,63,69 Houweling et al.63 reported total salary costs to be significantly lower in the intervention group (€114.6 ± 50.4) compared with the standard of care (€138.3 ± 48.3; p<0.001). In this same study, total costs for medication were reported to be lower, though not statistically significant, in the intervention groups (€136.3 ± 91.9) compared with control (€149.0 ± 94.4; p=NS) at study completion.

Inpatient costs were reported to be significantly lower in two other studies. One described total inpatient costs for the intervention group at $869,535 versus $1,702,682 for the control (p=0.02).60 The other reported decreases in costs by sex, with the intervention groups achieving a decrease of $606 for men and $888 for women with hypertension.69 Further, outpatient costs were reported to be lower, albeit nonsignificant, with total costs reported at $1,237,270 in the nurse-managed protocol group versus $1,381,900 in the control group (p=0.47).69

### Studies Targeting Congestive Heart Failure

Ten randomized trials evaluated nurse-managed protocols in 2836 patients with CHF.50,54,55,59,61,64,66,73-75 Table 5 summarizes the study and patient characteristics. A nurse-led clinic delivered the interventions in 5 studies.59,64,66,74,75 Supervision of the nurse was almost exclusively by a physician, usually a primary care physician, and in some instances, a cardiologist. Outcomes were assessed at 6 to 18 months, with most reporting outcomes at 12 months or later. All nurse interventionists were RNs or equivalent and did not meet the threshold of advanced practice nursing. Of the studies that reported the nurses' training, three used specialists (i.e., cardiac-certified), three reported study-specific training, and one used nurse case managers.

Table 5 Study and patient characteristics of included CHF studies^a^

Study Characteristics | Congestive Heart Failure Studies
N studies (N patients) | 10 (2836)
Study design: N studies (%)
RCT | 10 (100%)
Non-RCT | –
Setting: N studies (%)
General medical | –
Medical specialty | 3 (30%)
Telephone- and clinic-delivered care | 6 (60%)
Not reported/unclear | 1 (10%)
Intervention delivery: N studies
Clinic visits | 4
Primarily telephone | 5
Balance of visits and telephone | 1
Nurse training: N studies (%)
Specialist (i.e., clinical certification or diabetes nurse educator) | 4 (40%)
Received study-specific training | 5 (50%)
Case manager | –
Not described | 1 (10%)
Medication initiation: N studies (%) | 8 (80%)
Educational or behavioral strategies: N studies (%)
Education | 9 (90%)
Specific behavioral strategy (e.g., motivational interviewing) | 3 (30%)
Self-management plan | 5 (50%)
Risk of bias: N studies (%)
Low | 6 (60%)
Moderate | 4 (40%)
High | –
Patient characteristics
Age: median (range) | 72 (53 to 80)
Sex N patients (%)
Female | 988 (35%)
Male | 1870 (65%)
Race: N patients (%)
Black | 988 (35%)
Hispanic | 1870 (65%)
White | –
Other | –
Not reported | –
Disease severity: median (range)
NYHA, class I-II (%) | 50 (40.9 to 62)
NYHA, class III-IV (%) | 50 (38 to 59)
Not reported | 7 studies

a Excluded from this table is one study conducted in older adults with complex conditions that included diabetes, hypertension, and congestive heart failure.58

Abbreviations: CHF=congestive heart failure; NYHA=New York Heart Association

In nine studies, additional intervention was delivered by the nurse and included education, behavioral (i.e., motivational interviewing), or self-management. In six studies, the intervention was exclusively clinic-delivered, and in four studies either exclusively telephone-delivered or a combination of telephone- and clinic-delivered.

Overall, baseline characteristics demonstrate that most studies targeting patients with CHF had on average stage III (moderate) heart failure according to the New York Heart Association functional class. Measurement of left ventricular ejection fracture (LVEF) assessed during hospitalization of patients was not a focus of these studies and was not reliably reported.

We assessed risk of bias for each study and found that five studies had moderate risk of bias,54,59,64,66,74 and five had low risk.50,55,61,73,75 A rating of moderate risk was largely due to possible contamination from a concurrent intervention, unclear risk of protocol variation, or outcome assessors not blinded. Overall, there was low to moderate risk of bias in these studies.

#### Nursing Staff Satisfaction

None of the included studies reported on nursing staff satisfaction or their experience with the nurse-managed protocols.

#### Treatment Adherence

One study reported on treatment adherence,74 finding that the intervention group improved self-care behaviors more than the control group (p=0.02) and retained the improved self-care behaviors after 12 months, while the control group did not. At 12 months, 79 percent of the intervention group continued to weigh themselves compared with 41 percent in the control group (p<0.01). Participants in the intervention group compared with control were also better at alerting the health care system about weight gain (74% vs. 38%, p<0.01) and restricting fluid intake (50% vs. 28%, p=0.07), respectively.

#### Quality Measures

##### Biophysical Markers

Mortality. All 10 RCTs, involving 2836 patients, reported effects on all-cause mortality and were included in the quantitative analysis (Figure 10). ORs for mortality were significantly lower in the intervention groups compared with controls (OR 0.71; 95% CI, 0.52 to 0.96), with moderately inconsistent treatment effects (Q=15.97, df=9, p=0.07; I^2^=44%). Using the summary OR and median event rate from the control arm of the trials, we estimated the absolute treatment effect as a risk difference of 36 fewer deaths per 1000 patients (95% CI, 62 to 5 fewer). A funnel plot did not show evidence of publication bias (Appendix B).

Figure 10 Effects of nurse-managed protocols on mortality

Abbreviations: CI=confidence interval

We performed subgroup analyses to explore for differences in intervention effects between studies conducted in the United States compared with other countries, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. There were no telephone-based studies and no statistically significant differences in treatment effects for any of the other subgroup analyses (Appendix G).

Health-related quality of life (HRQOL). Four studies reported effects on general measures of HRQOL.50,66,73,75 Two of these found significant effects on the SF-36 physical health component: Angermann et al.,50 MD 2.1 (95% CI, 0.2 to 4.0), and Sisk et al.,73 MD 3.1 (95% CI, 0.7 to 5.5). In a small study by Thompson et al.,75 there was no statistically significant effect; however, the mean change in scores favored the intervention. In another study by Mejhert et al.,66 there was no reported effect. Thus, limited evidence suggests that nurse-managed protocols may have a small positive effect on HRQOL.

##### Process-of-Care Measures

ACE/ARB-prescribing. Six of the 10 CHF-focused studies reported on the process measure of ACE/ARB-prescribing. Figure 11 shows the forest plot of the random-effects meta-analysis of nurse-managed protocols on the process measure of ACE/ARB-prescribing. Though statistically not significant, nurse-managed protocols were more likely to achieve target ACE/ARB-prescribing goals than usual care (OR 1.15; 95% CI, 0.90 to 1.46). Using the summary OR and median event rate from the control arm of the trials, we estimated the absolute treatment effect as a risk difference of 18 more ACE/ARB-prescribing goals reached per 1000 patients (95% CI, -15 to 45 more).

Figure 11 Effects of nurse-managed protocols on ACE/ARB-prescribing goals

Abbreviations: ACE=angiotensin-converting enzyme; ARB=angiotensin receptor blocking; CI=confidence interval

We performed subgroup analyses to explore for differences in intervention effects between studies conducted in the United States versus other countries, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. There were no telephone-based studies and no statistically significant differences in treatment effects for any of the other subgroup analyses (Appendix G).

#### Resource Utilization

##### Hospitalizations

Of the 10 studies conducted in patients with CHF, 7 RCTs (2538 patients) reported on hospitalization and were included in the quantitative analyses. Compared with usual care, nurse-managed protocols were associated with fewer total hospitalizations (OR 0.83; 95% CI, 0.62 to 1.10) (Figure 12) and fewer CHF-related hospitalizations (OR 0.62; 95% CI, 0.49 to 0.80) (Figure 13). Though results were overall not statistically significant (p=0.20) , one study did report a statistically significant decrease in days of hospitalization in the nurse-managed protocol group compared with control (1.4 vs. 3.9, p=0.02).74

Figure 12 Effects of nurse-managed protocols on total hospitalizations

Abbreviations: CI=confidence interval

Figure 13 Effects of nurse-managed protocols on CHF-related hospitalizations

Abbreviations: CI=confidence interval

Using the summary OR and median event rate from the control arm of the RCTs, we estimated the absolute treatment effect as a risk difference of 32 fewer total hospitalizations per 1000 patients (95% CI, CI, 76 fewer to 18 more) and 42 fewer CHF-related hospitalizations per 1000 patients (95% CI, CI, 57 to 22 fewer).

Subgroup analyses were conducted to explore for differences in intervention effects between studies conducted in the United States versus other countries, studies incorporating self-management plans or specific behavioral interventions versus those that did not, and studies delivering the intervention primarily by clinic visits versus telephone interventions. These analyses showed greater effects for studies that incorporated self-management plans or specific behavioral interventions on decreasing the number CHF-related hospitalizations (OR 0.47 vs. 0.75, p=0.04). Thus, nurse-managed protocols were associated with an overall decrease in hospitalizations, but effects varied. Exploratory subgroup analysis suggests some of the variability in intervention effects may be explained by intervention intensity and content (Appendix G).

Figure 13 shows that CHF-related hospitalizations decreased significantly when nurse-managed protocols were used, with a consistent treatment effect. The study that reported total CHF-related hospital events (rate, not proportion) was not included in this analysis.64 This study did find however that total heart failure rehospitalizations were reduced by 84% (3 vs. 19, p = .02).64

##### Emergency Department (ED) Visits

ED visits were reported in two studies.55,73 No performance metrics for ED visits were reported. Debusk et al.55 reported virtually no differences between the number of patients in the intervention (55%) and control (56%) who were admitted to the ED (p>0.05). The study by Sisk et al.73 reported similar results with no difference in ED admissions in the nurse-managed protocol intervention group (33%) compared with the usual care group (37%) (p>0.05). Further, there was no significant difference in patients having more than one ED visit between the two groups (MD -5.7; 95% CI, -15.0 to 3.7).

##### Total Costs

Only one study reported costs of the nurse-managed protocol interventions.61 Mean cost for hospital readmission was significantly lower (-35%) in the intervention group (€843 ± 1733) compared with the control group (€1298 ± 2322; p<0.01).

### Studies Targeting Older Patients With Chronic Conditions

One study by Dorr, et al.58 targeted older patients (mean age = 76.2 years) with chronic conditions who had a combination of diabetes, hypertension, and CHF. This low-quality non-RCT of 3432 patients who were 96% white and 64.6% female used a disease-management program where an RN-equivalent used a protocol to titrate medications and deliver additional behavioral self-management and education in primary care clinics. Outcomes were reported at 12 and 104 months with a focus on mortality and resource utilization. Mortality was significantly lower at 12 months in the intervention compared with control (6.2% vs. 10.6% deaths, p<0.05). Total and CHF-related hospitalization rates were lower yet not significant at 12 months. At 2-year mortality, total and CHF-related hospitalizations continued to be lower though not significantly. However, ED visits increased in the nurse-managed protocol group compared with control, also not significant.

## KEY QUESTION 2 In studies of nurse-managed protocols, how well do participating nurses adhere to the protocol?

### Key Points

- Indirect evidence (e.g., improved outcomes) suggests that nurses adhere to protocols, but direct evidence (e.g., through fidelity checks) is insufficient to establish how well nurses adhere to protocols when engaged in delivering nurse-managed care.
- Only two of 29 included studies reported increased nurse adherence to treatment protocols.

Indirect evidence suggests that nurses adhere to protocols. Results from increased ACE/ARB treatment goals suggest nurses used the protocols. Two studies49,70 reported data on adherence to treatment protocols. When compared with usual care, nurses instituted pharmacological therapy for lipid management more often.49 DeBusk et al.70 reported that hypoglycemic agents and antihypertensives including ACE inhibitors, angiotensin 2 antagonists, and statins were started or doses increased by nurses following treatment protocols compared with usual care groups. However, there was no report of fidelity to the protocols (e.g., levels of titration, consultation with a supervisor). Thus, the data is insufficient to establish how well nurses adhere to protocols when engaged in delivering nurse-managed care.

## KEY QUESTION 3 Are there adverse effects associated with the use of nurse-managed protocols?

### Key Points

- Adverse events were reported in only one study.
- Evidence was insufficient to establish if there are adverse effects associated with the use of nurse-managed protocols.

There was a paucity of reported adverse events in the included studies (for details on mortality, refer to section above). Adverse events include, for example hypoglycemic or syncope episodes due to medication titration, wrong medications or dosage prescribed, drug-to-drug interactions, development of renal failure, or increased rates of injury such as falls. Only one fair-quality U.S. study on diabetes in a health maintenance organization by Aubert et al.51 reported on adverse events. Severe low blood glucose events were identical (1.5%) at baseline and increased similarly, 2.9% in the control group compared with 3.1% in the intervention group (p=0.158). Death did not occur in either group.