# REFERENCES

1 Institute of Medicine. Living Well with Chronic Illness: A Call to Public Health Action. National Academies of Science. Washington DC. 2012. Available at: http://www.iom.edu/˜/media/Files/Report%20Files/2012/Living-Well-with-Chronic-Illness/livingwell_chronicillness_reportbrief.pdf. June 6, 2013.
2 Vital signs: prevalence, treatment, and control of hypertension—United States, 1999–2002 and 2005–2008. MMWR Morb Mortal Wkly Rep. 2011;60(4):103-8. [pmid: 21293325].
3 Yach D, Hawkes C, Gould CL, et al. The global burden of chronic diseases: overcoming impediments to prevention and control. JAMA. 2004;291(21):2616-22. [pmid: 15173153].
4 Chobanian AV, Bakris GL, Black HR, et al. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension. 2003;42(6):1206-52. [pmid: 14656957].
5 Standards of medical care in diabetes—2013. Diabetes Care. Suppl 1. 2013;36:S11-66. [pmid: 23264422].
6 Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143-421. [pmid: 12485966].
7 Lindenfeld J, Albert NM, Boehmer JP, et al. HFSA 2010 Comprehensive Heart Failure Practice Guideline. J Card Fail. 2010;16(6):e1-194. [pmid: 20610207].
8 Smith SC Jr. Clinical treatment of dyslipidemia: practice patterns and missed opportunities. Am J Cardiol. 2000;86(12A):62L-65L.
9 Shafazand S, Yang Y, Amore E, et al. A retrospective, observational cohort analysis of a nationwide database to compare heart failure prescriptions and related health care utilization before and after publication of updated treatment guidelines in the United States. Clin Ther. 2010;32(9):1642-50. [pmid: 20974322].
10 Nichol MB, Knight TK, Priest JL, et al. Nonadherence to clinical practice guidelines and medications for multiple chronic conditions in a California Medicaid population. J Am Pharm Assoc (2003). 2010;50(4):496-507. [pmid: 20621868].
11 Doggrell SA. Adherence to medicines in the older-aged with chronic conditions: does intervention by an allied health professional help?. Drugs Aging. 2010;27(3):239-54. [pmid: 20210369].
12 Zuluaga A, Salas M, Gwadry-Sridhar FH, et al. Interventions to improve patients compliance with lipid lowering medications: A systematic review of the literature. Pharmacoepidemiology and Drug Safety. 2011;20:S356.
13 Jessup M, Albert NM, Lanfear DE, et al. ACCF/AHA/HFSA 2011 survey results: current staffing profile of heart failure programs, including programs that perform heart transplant and mechanical circulatory support device implantation. J Card Fail. 2011;17(5):349-58. [pmid: 21549290].
14 Arnold M, Kaan AM, Howlett J, et al. Specialized heart failure outpatient clinics: What staff are required, what is their workload, and can these data facilitate the planning of new heart failure clinics?. Journal of Cardiac Failure. 2011;17(8):S109.
15 Klein S. The Veterans Health Administration Implementing Patient-Centered Medical Homes in the Nation's Largest Integrated Delivery System, The Commonwealth Fund. September. 2011. Available at: http://www.commonwealthfund.org/Publications/Case-Studies/2011/Sep/VA-Medical-Homes.aspx#citation. June 5 2012.
16 Institute of Medicine. The Future of Nursing: Leading Change, Advancing Health Report Recommendations. National Academies of Science. Washington DC. 2010. Available at: http://www.iom.edu/˜/media/Files/Report%20Files/2010/The-Future-of-Nursing/Future%20of%20Nursing%202010%20Recommendations.pdf. June 6 2013.
17 Stanley JM. Advanced practice nursing: emphasizing common roles. 3rd ed. Philadelphia. F.A. Davis. 2011.
18 Tshiananga JK, Kocher S, Weber C, et al. The effect of nurse-led diabetes self-management education on glycosylated hemoglobin and cardiovascular risk factors: a meta-analysis. Diabetes Educ. 2012;38(1):108-23. [pmid: 22116473].
19 Joseph P, Teo K. Optimal medical therapy, lifestyle intervention, and secondary prevention strategies for cardiovascular event reduction in ischemic heart disease. Curr Cardiol Rep. 2011;13(4):287-95. [pmid: 21556974].
20 Allen JK, Dennison CR. Randomized trials of nursing interventions for secondary prevention in patients with coronary artery disease and heart failure: systematic review. J Cardiovasc Nurs. 2010;25(3):207-20. [pmid: 20386243].
21 Wilhelmsson S, Lindberg M. Prevention and health promotion and evidence-based fields of nursing - a literature review. Int J Nurs Pract. 2007;13(4):254-65. [pmid: 17640247].
22 Haskell WL. Cardiovascular disease prevention and lifestyle interventions: effectiveness and efficacy. J Cardiovasc Nurs. 2003;18(4):245-55. [pmid: 14518600].
23 McCauley KM, Bixby MB, Naylor MD. Advanced practice nurse strategies to improve outcomes and reduce cost in elders with heart failure. Dis Manag. 2006;9(5):302-10. [pmid: 17044764].
24 Barkauskas VH, Pohl JM, Tanner C, et al. Quality of care in nurse-managed health centers. Nurs Adm Q. 2011;35(1):34-43. [pmid: 21157262].
25 Newhouse RP, Stanik-Hutt J, White KM, et al. Advanced practice nurse outcomes 1990–2008: a systematic review. Nurs Econ. 2011;29(5):230-50. quiz 251. [pmid: 22372080].
26 Case R, Haynes D, Holaday B, et al. Evidence-based nursing: the role of the advanced practice registered nurse in the management of heart failure patients in the outpatient setting. Dimens Crit Care Nurs. 2010;29(2):57-62. [pmid: 20160538].
27 U.S. Department of Health and Human Services. Centers for Medicare & Medicaid Services Memorandum. October. 24. 2008. Available at: http://www.cms.gov/Medicare/Provider-Enrollment-and-Certification/SurveyCertificationGenInfo/downloads/SCLetter09–10.pdf.
28 Watts SA, Lawrence RH, Kern E. Diabetes nurse case management training program: enhancing care consistent with the chronic care and patient-centered medical home models. Clin Diabetes. 2011;(29):25-33.
29 Moher D, Liberati A, Tetzlaff J, et al. The PRISMA Group. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS Med. 2009;6(7):e1000097. [pmid: 19621072].
30 Berra K. Does nurse case management improve implementation of guidelines for cardiovascular disease risk reduction?. J Cardiovasc Nurs. 2011;26(2):145-67. [pmid: 21076315].
31 Brown SA. Meta-analysis of diabetes patient education research: variations in intervention effects across studies. Res Nurs Health. 1992;15(6):409-19. [pmid: 1448572].
32 Clark CE, Smith LF, Taylor RS, et al. Nurse led interventions to improve control of blood pressure in people with hypertension: systematic review and meta-analysis. BMJ. 2010;341:c3995. [pmid: 20732968].
33 Clark CE, Smith LF, Taylor RS, et al. Nurse-led interventions used to improve control of high blood pressure in people with diabetes: a systematic review and meta-analysis. Diabet Med. 2011;28(3):250-61. [pmid: 21309833].
34 Driscoll A, Currey J, Tonkin A, et al. Nurse-led titration of angiotensin converting enzyme inhibitors, beta-adrenergic blocking agents and angiotensin receptor blockers for patients with left ventricular systolic dysfunction. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
35 Glynn LG, Murphy AW, Smith SM, et al. Interventions used to improve control of blood pressure in patients with hypertension. Cochrane Database Syst Rev. 2010;(3):CD005182. [pmid: 20238338].
36 Loveman E, Royle P, Waugh N. Specialist nurses in diabetes mellitus. Cochrane Database Syst Rev. 2003;(2):CD003286. [pmid: 12804458].
37 Takeda A, Taylor SJ, Taylor RS, et al. Clinical service organisation for heart failure. Cochrane Database Syst Rev. 2012;9:CD002752. [pmid: 22972058].
38 Welch G, Garb J, Zagarins S, et al. Nurse diabetes case management interventions and blood glucose control: results of a meta-analysis. Diabetes Res Clin Pract. 2010;88(1):1-6. [pmid: 20116879].
39 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. Available at: www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318. March 16, 2012.
40 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. AHRQ Methods for Effective Health Care [Internet]. Rockville (MD). Agency for Healthcare Research and Quality (US). 2008. Available from: http://www.ncbi.nlm.nih.gov/books/NBK49468/. May 20, 2012.
41 Higgins JPT, Deeks JJ, Altman DG, editors. Chapter 16: Special topics in statistics. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011]. The Cochrane Collaboration. 2011. Available from www.cochrane-handbook.org.
42 Deeks JJ, Higgins JPT, editors. Chapter 9: Analysing data and undertaking meta-analysis. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0. [updated March 2011 ]. The Cochrane Collaboration. 2011. Available from www.cochrane-handbook.org.
43 Taylor CB, Miller NH, Reilly KR, et al. Evaluation of a nurse-care management system to improve outcomes in patients with complicated diabetes. Diabetes Care. 2003;26(4):1058-63. [pmid: 12663573].
44 Balshem H, Helfand M, Schunemann HJ, et al. GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401-6. [pmid: 21208779].
45 Konstam V, Gregory D, Chen J, et al. Health-related quality of life in a multicenter randomized controlled comparison of telephonic disease management and automated home monitoring in patients recently hospitalized with heart failure: SPAN-CHF II trial. J Card Fail. 2011;17(2):151-7. [pmid: 21300305].
46 Rao A, Walsh J. Impact of specialist care in patients with newly diagnosed heart failure: a randomised controlled study. Int J Cardiol. 2007;115(2):196-202. [pmid: 16814411].
47 Senaratne MP, Griffiths J, Mooney D, et al. Effectiveness of a planned strategy using cardiac rehabilitation nurses for the management of dyslipidemia in patients with coronary artery disease. Am Heart J. 2001;142(6):975-81. [pmid: 11717600].
48 Varney S. A cost-effectiveness analysis of bisoprolol for heart failure. Eur J Heart Fail. 2001;3(3):365-71. [pmid: 11378009].
49 Allison TG, Squires RW, Johnson BD, et al. Achieving National Cholesterol Education Program goals for low-density lipoprotein cholesterol in cardiac patients: importance of diet, exercise, weight control, and drug therapy. Mayo Clin Proc. 1999;74(5):466-73. [pmid: 10319076].
50 Angermann CE, Stork S, Gelbrich G, et al. Mode of action and effects of standardized collaborative disease management on mortality and morbidity in patients with systolic heart failure: the Interdisciplinary Network for Heart Failure (INH) study. Circ Heart Fail. 2012;5(1):25-35. [pmid: 21956192].
51 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Ann Intern Med. 1998;129(8):605-12. [pmid: 9786807].
52 Bebb C, Kendrick D, Coupland C, et al. A cluster randomised controlled trial of the effect of a treatment algorithm for hypertension in patients with type 2 diabetes. Br J Gen Pract. 2007;57(535):136-43. [pmid: 17263930].
53 Bellary S, O'Hare JP, Raymond NT, et al. Enhanced diabetes care to patients of south Asian ethnic origin (the United Kingdom Asian Diabetes Study): a cluster randomised controlled trial. Lancet. 2008;371(9626):1769-76. [pmid: 18502301].
54 Berger R, Moertl D, Peter S, et al. N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol. 2010;55(7):645-53. [pmid: 20170790].
55 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. Ann Intern Med. 2004;141(8):606-13. [pmid: 15492340].
56 DeBusk RF, Miller NH, Superko HR, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Ann Intern Med. 1994;120(9):721-9. [pmid: 8147544].
57 Denver EA, Barnard M, Woolfson RG, et al. Management of uncontrolled hypertension in a nurse-led clinic compared with conventional care for patients with type 2 diabetes. Diabetes Care. 2003;26(8):2256-60. [pmid: 12882845].
58 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. 2008;56(12):2195-202. [pmid: 19093919].
59 Ekman I, Fagerberg B, Andersson B, et al. Can treatment with angiotensin-converting enzyme inhibitors in elderly patients with moderate to severe chronic heart failure be improved by a nurse-monitored structured care program? A randomized controlled trial. Heart Lung. 2003;32(1):3-9. [pmid: 12571543].
60 Fischer HH, Eisert SL, Everhart RM, et al. Nurse-run, telephone-based outreach to improve lipids in people with diabetes. Am J Manag Care. 2012;18(2):77-84. [pmid: 22435835].
61 Giordano A, Scalvini S, Zanelli E, et al. Multicenter randomised trial on home-based telemanagement to prevent hospital readmission of patients with chronic heart failure. Int J Cardiol. 2009;131(2):192-9. [pmid: 18222552].
62 Houweling ST, Kleefstra N, van Hateren KJ, et al. Can diabetes management be safely transferred to practice nurses in a primary care setting? A randomised controlled trial. J Clin Nurs. 2011;20(9–10):1264-72. [pmid: 21401764].
63 Houweling ST, Kleefstra N, van Hateren KJ, et al. Diabetes specialist nurse as main care provider for patients with type 2 diabetes. Neth J Med. 2009;67(7):279-84. [pmid: 19687522].
64 Krantz MJ, Havranek EP, Haynes DK, et al. Inpatient initiation of beta-blockade plus nurse management in vulnerable heart failure patients: a randomized study. J Card Fail. 2008;14(4):303-9. [pmid: 18474343].
65 MacMahon Tone J, Agha A, Sherlock M, et al. An intensive nurse-led, multi-interventional clinic is more successful in achieving vascular risk reduction targets than standard diabetes care. Ir J Med Sci. 2009;178(2):179-86. [pmid: 19367427].
66 Mejhert M, Kahan T, Persson H, et al. Limited long term effects of a management programme for heart failure. Heart. 2004;90(9):1010-5. [pmid: 15310688].
67 Meulepas MA, Braspenning JC, de Grauw WJ, et al. Patient-oriented intervention in addition to centrally organised checkups improves diabetic patient outcome in primary care. Qual Saf Health Care. 2008;17(5):324-8. [pmid: 18842969].
68 New JP, Mason JM, Freemantle N, et al. Educational outreach in diabetes to encourage practice nurses to use primary care hypertension and hyperlipidaemia guidelines (EDEN): a randomized controlled trial. Diabet Med. 2004;21(6):599-603. [pmid: 15154946].
69 New JP, Mason JM, Freemantle N, et al. Specialist nurse-led intervention to treat and control hypertension and hyperlipidemia in diabetes (SPLINT): a randomized controlled trial. Diabetes Care. 2003;26(8):2250-5. [pmid: 12882844].
70 O'Hare JP, Raymond NT, Mughal S, et al. Evaluation of delivery of enhanced diabetes care to patients of South Asian ethnicity: the United Kingdom Asian Diabetes Study (UKADS). Diabet Med. 2004;21(12):1357-65. [pmid: 15569141].
71 Philis-Tsimikas A, Walker C, Rivard L, et al. Improvement in diabetes care of underinsured patients enrolled in project dulce: a community-based, culturally appropriate, nurse case management and peer education diabetes care model. Diabetes Care. 2004;27(1):110-5. [pmid: 14693975].
72 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. 2004;17(10):921-7. [pmid: 15485755].
73 Sisk JE, Hebert PL, Horowitz CR, et al. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. 2006;145(4):273-83. [pmid: 16908918].
74 Stromberg A, Martensson J, Fridlund B, et al. Nurse-led heart failure clinics improve survival and self-care behaviour in patients with heart failure: results from a prospective, randomised trial. Eur Heart J. 2003;24(11):1014-23. [pmid: 12788301].
75 Thompson DR, Roebuck A, Stewart S. Effects of a nurse-led, clinic and home-based intervention on recurrent hospital use in chronic heart failure. Eur J Heart Fail. 2005;7(3):377-84. [pmid: 15718178].
76 Wallymahmed ME, Morgan C, Gill GV, et al. Nurse-led cardiovascular risk factor intervention leads to improvements in cardiovascular risk targets and glycaemic control in people with Type 1 diabetes when compared with routine diabetes clinic attendance. Diabet Med. 2011;28(3):373-9. [pmid: 21204963].
77 Berra K, Miller NH, Fair JM. Cardiovascular disease prevention and disease management: A critical role for nursing. J Cardiopulm Rehabil. 2006;26(4):197-206. [pmid: 16926682].
78 Glasziou P, Chalmers I, Altman DG, et al. Taking healthcare interventions from trial to practice. BMJ. 2010;341:c3852. [pmid: 20709714].
79 Carey N, Courtenay M. Nurse supplementary prescribing for patients with diabetes: a national questionnaire survey. J Clin Nurs. 2008;17(16):2185-93. [pmid: 18705738].
80 American Nursing Association. What Nurses Do. Available at: http://www.nursingworld.org/EspeciallyForYou/What-is-Nursing/Tools-You-Need/RNsAPNs.html. August 5th 2013.
81 APRN Joint Dialogue Group Report. Consensus Model for APRN Regulation: Licensure, Accreditation, Certification & Education. 2008. https://www.ncsbn.org/7_23_08_Consensue_APRN_Final.pdf. August 5th 2013.
82 Halcomb E, Davidson P, Daly J, et al. Australian nurses in general practice based heart failure management: implications for innovative collaborative practice. Eur J Cardiovasc Nurs. 2004;3(2):135-47. [pmid: 15234318].
83 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for Determining Research Gaps During Systematic Reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290–2007–10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. May 22, 2012.