# METHODS

## TOPIC DEVELOPMENT

This review was commissioned by the VA's Evidence-based Synthesis Program. We followed a standard protocol for this review; certain methods map to the PRISMA checklist.29 The topic was nominated after a process that included a preliminary review of published peer-reviewed literature and consultation with investigators, VA and non-VA experts, and key stakeholders (Office of Nursing Services, PACTs, and Primary Care Services).

The Key Questions (KQs) are:

KQ 1 For adults with chronic medical conditions, do nurse-managed protocols compared with usual care improve the following outcomes?
  - Nursing staff experience (e.g., satisfaction)
  - Treatment adherence
  - Quality measures such as
    ○ Biophysical markers (e.g., laboratory or physiological markers of health status such as HbA1c and blood pressure)
    ○ Process-of-care measures used by VA, National Quality Forum, or National Committee for Quality Assurance
  - Resource utilization
KQ 2 In studies of nurse-managed protocols, how well do participating nurses adhere to the protocol?
KQ 3 Are there adverse effects associated with the use of nurse-managed protocols?

## ANALYTIC FRAMEWORK

Our approach was guided by the analytic framework shown in Figure 1.

Figure 1 Analytic framework for nurse-managed protocols

Abbreviations: QOL=quality of life

## SEARCH STRATEGY

We conducted a primary review of the literature by systematically searching, reviewing, and analyzing the scientific evidence as it pertains to the KQs. To identify relevant articles, in consultation with a master librarian, we searched MEDLINE^®^ (via PubMed^®^), Cochrane Central Register of Controlled Trials, Embase^®^, and CINAHL^®^ from January 1, 1980, to December 12, 2012, for peer-reviewed publications evaluating interventions that used nurse-managed protocols compared with usual care in studies targeting adults with diabetes, hypertension, hyperlipidemia, CHF, or chronic conditions.

Terms such as “RN protocols” or “nurse protocols,” are not yet found as key words or medical subject headings (MeSH terms) in the Library of Medicine. Therefore, we selected exemplary articles and used MeSH Analyzer (http://www.docmobi.com/mesh/) to identify high-frequency keywords supplemented with selected free-text terms used to search titles and abstracts (Appendix A). We added validated search terms for both randomized controlled trials and relevant observational studies adapted from recommendations by the Cochrane Effective Practice and Organization of Care Group. We limited the search to articles published in the English language involving human subjects 18 years of age and older. We further searched the bibliographies of exemplar studies and applicable systematic reviews for missed publications.18,20,25,30-38 To assess for publication bias, we searched ClinicalTrials.gov to identify completed but unpublished studies meeting our eligibility criteria, an indicator of possible publication bias, but none were found as of May 30, 2013 (Appendix B).

All citations were imported into two electronic databases (for referencing, EndNote^®^ Version X5, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## STUDY SELECTION

Using prespecified inclusion and exclusion criteria, two reviewers assessed titles and abstracts for relevance to the KQs. Full-text articles identified by either reviewer as potentially relevant were retrieved for further review and examined by two reviewers against the eligibility criteria. Disagreements on inclusion, exclusion, or the major reason for exclusion were resolved by discussion or by a third reviewer. The criteria to screen articles for inclusion or exclusion at both the title-and-abstract and full-text screening stages are detailed in Table 3.

Table 3 Summary of inclusion and exclusion criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adults (≥18 years of age) with diabetes, hypertension, hyperlipidemia, congestive heart failure, or combinations of these chronic medical conditions. In mixed samples, ≥ 80% of the sample must be selected for one of the 4 target conditions. Outpatients in a primary care setting or specialty clinic/practice. Studies with patients enrolled during a hospitalization if the majority of the intervention is delivered on an outpatient basis. | Gestational diabetes
Intervention | Intervention must involve an RN or LPN functioning beyond the usual scope of practice, which must include adjustment of medications. Activities must be based on a written protocol that specifies the scope of practice and is designed to support longitudinal care for chronic conditions. Interventions may be delivered by telephone or face-to-face visits. | Care plans Protocols limited to telephone triage Telecare limited to symptom or vital sign monitoring and information support Disease management protocols limited to educational interventions or assessment of treatment response
Comparator | Usual outpatient care or other quality-improvement strategy | None
Outcome | KQ 1: Study must report at least 1 of the following relevant outcomes:; - Nursing staff experience using validated measures; - Treatment adherence to medication or behavioral/lifestyle recommendations; - Laboratory or physiological markers of health status such as HbA1c and blood pressure (prioritizing measures associated with accepted indicators of quality of care); - Nationally recognized performance metrics related to the conditions of interest (e.g., foot exams in diabetes or proportion of patients meeting a treatment goal); - Utilization of medical resources (prioritizing hospitalizations or emergency department visits related to the condition) or health care costs (prioritizing total, inpatient and primary care outpatient costs); KQ 2: Fidelity to the nurse-managed protocol KQ 3: Adverse effects, particularly drug-related adverse effects including drug-drug interactions | No relevant outcomes
Timing | Outcomes reported ≥3 months from randomization and initiation of intervention | Outcomes reported <3 months from randomization and initiation of intervention
Setting | Outpatient setting Studies conducted in North America, Western Europe, Australia/New Zealand, and selected Caribbean countries^a^ | Care model where the intervention is delivered primarily in the patient's home or community setting (e.g., community centers, workplace settings)
Study design | Study designs recommended by the Cochrane Effective Practice and Organization of Care Group:; - Patient or cluster randomized controlled trials; - Nonrandomized cluster controlled trials: experimental studies in which practices or clinicians are allocated to different interventions using a nonrandom method; - Controlled before-and-after studies: studies in which observations are made before and after the implementation of an intervention, both in an intervention group and a control group; - Interrupted time-series designs: studies that use observations at multiple time points before and after an intervention. Interrupted time series must have at least 3 measurement points prior to and after the intervention is begun. | Cross-sectional studies and other observational study designs not specifically listed as “included” study designs
Publications | English-language only Published from 1980 to present^b^ Peer-reviewed, full publication | Non-English language Published before 1980 Abstract only

a Rationale is to include economically developed countries with sufficient similarities in health care system and culture to be applicable to U.S. medical care.

b Rationale is that prior to 1980, nursing education differed importantly from contemporary training; e.g., physical examination was not taught.

Abbreviations: KQ=key question; HbA1c=glycosylated hemoglobin; LPN=licensed practical nurse; RN=registered nurse

## DATA ABSTRACTION

Before general use, the abstraction form templates, designed specifically for this report, were piloted on a sample of included articles and revised to ensure that all relevant data elements were captured and that there was consistency and reproducibility between abstractors. Key characteristics abstracted include patient descriptors, setting, features of the nurse-managed protocol intervention and comparator, outcomes, and quality elements. Multiple reports from a single study were treated as a single data point. When critical data were missing or unclear, we contacted the study authors. Of 44 authors contacted, 30 responded with the requested information.

Key features relevant to applicability included the match between the sample and target populations (e.g., severity, comorbidity, age) and the training and experience of the nurse. Because many studies were conducted outside the United States, we queried authors regarding the education and scope of practice of the nurse interventionists to determine if they were closer to the U.S. equivalent of an LPN, RN, or NP (Appendix C). Selected data from published reports were then abstracted into the final abstraction form by a trained reviewer. All data abstractions were confirmed by a second reviewer. Disagreements were resolved by consensus or by obtaining a third reviewer's opinion.

We abstracted the following key information for each included study:

- Study characteristics
  ○ Study design, funding source
  ○ Location (country and institution) and setting (clinic, etc.) of study
  ○ Health care system involved
  ○ Types of comparison groups
  ○ Inclusion/exclusion criteria (eligible diagnoses, etc.)
  ○ Number of subjects eligible for, randomized, or enrolled in and completed study
- Population characteristics
  ○ Sex, race, and age of sample
  ○ Inclusion of active duty or Veteran subjects
  ○ Baseline severity of symptoms or markers of conditions of interest (e.g., HbA1c)
  ○ Baseline performance measures
- Description of the intervention
  ○ Medical conditions addressed by intervention
  ○ Nurse's education level, special training, or certification
  ○ Supervision of nurse-led clinics, nurse leaders
  ○ Guideline or algorithm used
  ○ Scope of nurse's role (medication initiation and/or adjustment, etc.)
  ○ Other aspects of program (education, behavioral plan, self-management)
  ○ Mode of delivery (clinic, telephone, etc.)
  ○ Duration of intervention, number of planned and delivered visits
- Outcomes
  ○ Time points measured
  ○ Nursing staff satisfaction
  ○ Adherence (to protocol, medications, behavioral components)
  ○ Health-related quality of life
  ○ All-cause and CHF-related mortality
  ○ Biophysical markers (HbA1c, blood pressure, cholesterol, etc.)
  ○ Performance measures
  ○ Resource utilization (cost, hospitalizations, emergency department visits, etc.)
  ○ Adverse effects
  ○ Results from subgroup or sensitivity analyses

## RISK OF BIAS (QUALITY) ASSESSMENT

We abstracted data necessary to assess the risk of bias of included studies. Across all included studies, quality criteria were applied for each study by two independent reviewers (Appendix D). Disagreements were resolved between the two reviewers or, when needed, by arbitration from a third reviewer. We used the key risk of bias criteria described in the Agency for Healthcare Research and Quality's (AHRQ's) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”39 adapted to this specific topic and customized to RCTs and quasi-experimental designs. For RCTs, these criteria were adequacy of randomization and allocation concealment, the comparability of groups at baseline, blinding, the completeness of followup and differential loss to followup, whether incomplete data were addressed appropriately, the validity of outcome measures, and conflict of interest. For observational studies, we adapted AHRQ's risk of bias rating for observational studies40 that addresses specific issues in the general areas of selection bias, performance bias, detection bias, and reporting bias. We assigned a summary risk of bias score (low, moderate, or high) to individual studies.

## DATA SYNTHESIS

While synthesizing relevant abstracted data, we developed a summary table describing the key outcomes and the types of study designs used to test nurse-managed protocol interventions. We then determined the feasibility of completing a quantitative synthesis (i.e., meta-analysis) to estimate summary effects. Feasibility depends on the volume of relevant literature, conceptual homogeneity of the studies, and completeness of results reporting. For studies with unique but conceptually similar outcomes (e.g., ordering a guideline-indicated laboratory test), we synthesized outcomes across conditions if intervention effects were sufficiently homogeneous. As a result, analyses were grouped into two major categories: (1) studies targeting cardiovascular risk factors—hyperglycemia, hypertension, hyperlipidemia and (2) studies targeting CHF.

When meta-analysis was feasible, we explored the possibility of subgroup analyses to examine the consistency of effects across chronic diseases for common outcomes. Subgroup analyses involve indirect comparisons (across studies) and are subject to confounding. Thus, results were interpreted cautiously and are considered hypothesis-generating. Where quantitative synthesis was possible (as for KQ 1), dichotomous outcomes were combined using odds ratios (ORs), and continuous outcomes were combined using mean differences (MDs) in a random-effects model. To facilitate interpretation of summary ORs, we calculated the absolute risk difference using the median event rate in the control groups together with the summary ORs. For categories with multiple potential outcomes (e.g., biophysical markers) that may vary across chronic conditions, we selected a priori the outcomes to analyze for each chronic condition: HbA1c for diabetes, blood pressure for hypertension, cholesterol for hyperlipidemia, and mortality for CHF. All outcomes were transformed to common units (e.g., cholesterol values transformed to mg/dl). For meta-analyses, we used established methods41,42 to estimate means and standard deviations (SDs) when outcomes were reported in other formats. In one instance,43 we imputed missing SDs using estimates from similar studies. Using subgroup analyses, we explored potential sources of heterogeneity including studies conducted in the United States, the number of conditions targeted by the intervention, intervention delivery mode (telephone vs. visits), and intervention content (including self-management or behavioral strategies). We evaluated for statistical heterogeneity using Cochrane's Q and I^2^ statistics. Publication bias was assessed using findings from a ClinicalTrials.gov search and funnel plots when at least 10 studies were included in the analysis (Appendix B).

Where quantitative synthesis was not feasible (as for KQs 2 and 3), we analyzed the data qualitatively. We gave more weight to the evidence from higher quality studies with more precise estimates of effect. The qualitative syntheses focused on documenting and identifying patterns in efficacy and safety of the intervention across conditions and outcome categories. We also analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## RATING THE STRENGTH OF EVIDENCE

In addition to rating the quality of individual studies, we evaluated the overall strength of evidence for each KQ as described in the “Methods Guide.”39 In brief, this approach requires assessment of four domains: risk of bias, consistency, directness, and precision. Additional domains considered were impact of plausible confounders and publication bias.44 These domains were considered qualitatively, and a summary rating of high, moderate, low, or insufficient strength of evidence was assigned after discussion by two reviewers. The five-level rating scale consists of the following definitions:

- High – We are very confident that the true effect lies close to that of the estimate of the effect.
- Moderate – We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.
- Low – Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.
- Insufficient – Evidence on an outcome is absent or too weak, sparse, or inconsistent to estimate an effect.

When a rating of high, moderate, low, or very low was not possible or was imprudent to make, a rating of insufficient was assigned.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. A transcript of their comments can be found in Appendix E, which elucidates how each comment was considered in the final report.