# SUBGROUP ANALYSES

Table G-1 Subgroup analyses^a,b^

Outcome | Non-US vs. US | Telephone vs. in-person | Single vs. multiple intervention target | Education with self-management or behavioral vs. not
Cardiovascular risk studies
A1c (MD) | -0.2 (I^2^=34%) vs. -0.92 (I^2^=0%) p=0.0003 | No studies in telephone group | -1.1 (1 study) vs. -0.31 (I^2^=55%) p=0.005 | -0.46 (I^2^=84%) vs. 0.35 (I^2^=16%) p=0.64
Systolic blood pressure (MD) | -3.24 (I^2^=76%) vs. -6.55 (I^2^=0%) p=0.17 | -8.50 (1 study) vs. -3.27 (I^2^=74%) p=0.10 | -5.47 (I^2^=85%) vs. -3.51 (I^2^=74%) p=0.62 | -2.12 (I^2^=61%) vs. -5.86 (I^2^=83%) p=0.15
Diastolic blood pressure (MD) | -1.58 (I^2^=75%) vs. -1.49 (I^2^=54%) p=0.96 | -3.10 (1 study) vs. -1.46 (I^2^=74%) p=0.31 | -1.27 (I^2^=63%) vs. -1.71 (I^2^=73%) p=0.75 | -1.36 (I^2^=71%) vs. -1.99 (I^2^=76%) p=0.62
Blood pressure performance measure (OR) | 1.41 (I^2^=77%) vs. 1.50 (1 study) p=0.87 | No studies in telephone group | 2.06 (I^2^=84%) vs. 1.39 (I^2^=75%) p=0.56 | 1.10 (I^2^=22%) vs. 1.94 (I^2^=80%) p=0.07
Total cholesterol (MD) | -7.61 (I^2^=89%) vs. -12.71 (I^2^=85%) p=0.55 | -24.33 (1 study) vs. -7.17 (I^2^=91%) p=0.0008 | -14.17 (I^2^=90%) vs. -7.79 (I^2^=87%) p=0.58 | -10.62 (I^2^=95%) vs. -8.17 (I^2^=85%) p=0.80
LDL cholesterol (MD) | -11.94 (I^2^=91%) vs. -12.21 (I^2^=91%) p=0.98 | -24.7 (1 study) vs. -9.22 (I^2^=85%) p=0.03 | -11.67 (I^2^=95%) vs. -12.18 (I^2^=86%) p=0.97 | -19.72 (I^2^=73%) vs. -8.32 (I^2^=89%) p=0.28
Cholesterol performance measure (OR) | 1.31 (I^2^=79%) vs. 1.85 (I^2^=82%) p=0.29 | 2.6 (I^2^=91%) vs. 1.28 (I^2^=73%) p=0.12 | 2.12 (I^2^=92%) vs. 1.37 (I^2^=79%) p=0.53 | 1.51 (I^2^=91%) vs. 1.60 (I^2^=74%) p=0.89
Congestive heart failure studies
Death (OR) | 0.67 (I^2^=59%) vs. 0.83 (I^2^=0%) p=0.48 | 0.64 (I^2^=0%) vs. 1.18 (I^2^=0%) p=0.02 | NA | 0.72 (I^2^=51%) vs. 0.67 (I^2^=44%) p=0.82
Hospitalizations (OR) | 0.77 (I^2^=74%) vs. 0.91 (I^2^=13%) p=0.55 | 0.87 (I^2^=63%) vs. 0.66 (I^2^=75%) p=0.61 | NA | 0.91 (I^2^=47%) vs. 0.58 (1 study) p=0.07
CHF Hospitalizations (OR) | 0.56 (I^2^=38%) vs. 0.74 (I^2^=0%) p=0.27 | No studies in in-person group | NA | 0.75 (I^2^=0%) vs. 0.47 (I^2^=0%) p=0.04
ACE/ARB performance measure (OR) | 1.10 (I^2^=0%) vs. 1.35 (1 study) p=0.51 | 1.2 (I^2^=0%) vs. 1.03 (I^2^=25%) p=0.61 | NA | 1.12 (I^2^=0%) vs. 1.26 (I^2^=0%) p=0.71

a If statistically significant main differences were found, the results are presented in bold type.

b If statistically significant subgroup differences were found, the group showing the larger effect is identified. Abbreviations: ACE/ARB=angiotensin-converting enzyme inhibitor/angiotensin receptor blocking; CHF=congestive heart failure; LDL=low-density lipoprotein; MD=mean difference; OR=odds ratio