# STUDY CHARACTERISTICS TABLE

Table F-1 Characteristics of included studies

## REFERENCES CITED IN APPENDIX F

1 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. A randomized, controlled trial. Ann Intern Med. 1998;129(8):605-12. [pmid: 9786807].
2 Bellary S, O'Hare JP, Raymond NT, et al. Enhanced diabetes care to patients of south Asian ethnic origin (the United Kingdom Asian Diabetes Study): a cluster randomised controlled trial. Lancet. 2008;371(9626):1769-76. [pmid: 18502301].
3 Fischer HH, Eisert SL, Everhart RM, et al. Nurse-run, telephone-based outreach to improve lipids in people with diabetes. Am J Manag Care. 2012;18(2):77-84. [pmid: 22435835].
4 Fischer H, Mackenzie T, McCullen K, et al. Design of a nurse-run, telephone-based intervention to improve lipids in diabetics. Contemp Clin Trials. 2008;29(5):809-16. [pmid: 18606250].
5 Houweling ST, Kleefstra N, van Hateren KJ, et al. Diabetes specialist nurse as main care provider for patients with type 2 diabetes. Neth J Med. 2009;67(7):279-84. [pmid: 19687522].
6 Houweling ST, Kleefstra N, van Hateren KJ, et al. Can diabetes management be safely transferred to practice nurses in a primary care setting? A randomised controlled trial. J Clin Nurs. 2011;20(9-10):1264-72. [pmid: 21401764].
7 MacMahon Tone J, Agha A, Sherlock M, et al. An intensive nurse-led, multi-interventional clinic is more successful in achieving vascular risk reduction targets than standard diabetes care. Ir J Med Sci. 2009;178(2):179-86. [pmid: 19367427].
8 Meulepas MA, Braspenning JC, de Grauw WJ, et al. Patient-oriented intervention in addition to centrally organised checkups improves diabetic patient outcome in primary care. Qual Saf Health Care. 2008;17(5):324-8. [pmid: 18842969].
9 New JP, Mason JM, Freemantle N, et al. Specialist nurse-led intervention to treat and control hypertension and hyperlipidemia in diabetes (SPLINT): a randomized controlled trial. Diabetes Care. 2003;26(8):2250-5. [pmid: 12882844].
10 Mason JM, Freemantle N, Gibson JM, et al. Specialist nurse-led clinics to improve control of hypertension and hyperlipidemia in diabetes: economic analysis of the SPLINT trial. Diabetes Care. 2005;28(1):40-6. [pmid: 15616231].
11 New JP, Mason JM, Freemantle N, et al. Educational outreach in diabetes to encourage practice nurses to use primary care hypertension and hyperlipidaemia guidelines (EDEN): a randomized controlled trial. Diabet Med. 2004;21(6):599-603. [pmid: 15154946].
12 Philis-Tsimikas A, Walker C, Rivard L, et al. Improvement in diabetes care of underinsured patients enrolled in project dulce: a community-based, culturally appropriate, nurse case management and peer education diabetes care model. Diabetes Care. 2004;27(1):110-5. [pmid: 14693975].
13 Taylor CB, Miller NH, Reilly KR, et al. Evaluation of a nurse-care management system to improve outcomes in patients with complicated diabetes. Diabetes Care. 2003;26(4):1058-63. [pmid: 12663573].
14 Wallymahmed ME, Morgan C, Gill GV, et al. Nurse-led cardiovascular risk factor intervention leads to improvements in cardiovascular risk targets and glycaemic control in people with Type 1 diabetes when compared with routine diabetes clinic attendance. Diabet Med. 2011;28(3):373-9. [pmid: 21204963].
15 Bebb C, Kendrick D, Coupland C, et al. A cluster randomised controlled trial of the effect of a treatment algorithm for hypertension in patients with type 2 diabetes. Br J Gen Pract. 2007;57(535):136-43. [pmid: 17263930].
16 Denver EA, Barnard M, Woolfson RG, et al. Management of uncontrolled hypertension in a nurse-led clinic compared with conventional care for patients with type 2 diabetes. Diabetes Care. 2003;26(8):2256-60. [pmid: 12882845].
17 O'Hare JP, Raymond NT, Mughal S, et al. Evaluation of delivery of enhanced diabetes care to patients of South Asian ethnicity: the United Kingdom Asian Diabetes Study (UKADS). Diabet Med. 2004;21(12):1357-65. [pmid: 15569141].
18 Rudd P, Miller NH, Kaufman J, et al. Nurse management for hypertension. A systems approach. Am J Hypertens. 2004;17(10):921-7. [pmid: 15485755].
19 Allison TG, Squires RW, Johnson BD, et al. Achieving National Cholesterol Education Program goals for low-density lipoprotein cholesterol in cardiac patients: importance of diet, exercise, weight control, and drug therapy. Mayo Clin Proc. 1999;74(5):466-73. [pmid: 10319076].
20 DeBusk RF, Miller NH, Superko HR, et al. A case-management system for coronary risk factor modification after acute myocardial infarction. Ann Intern Med. 1994;120(9):721-9. [pmid: 8147544].
21 Angermann CE, Stork S, Gelbrich G, et al. Mode of action and effects of standardized collaborative disease management on mortality and morbidity in patients with systolic heart failure: the Interdisciplinary Network for Heart Failure (INH) study. Circ Heart Fail. 2012;5(1):25-35. [pmid: 21956192].
22 Berger R, Moertl D, Peter S, et al. N-terminal pro-B-type natriuretic peptide-guided, intensive patient management in addition to multidisciplinary care in chronic heart failure a 3-arm, prospective, randomized pilot study. J Am Coll Cardiol. 2010;55(7):645-53. [pmid: 20170790].
23 DeBusk RF, Miller NH, Parker KM, et al. Care management for low-risk patients with heart failure: a randomized, controlled trial. Ann Intern Med. 2004;141(8):606-13. [pmid: 15492340].
24 Ekman I, Fagerberg B, Andersson B, et al. Can treatment with angiotensin-converting enzyme inhibitors in elderly patients with moderate to severe chronic heart failure be improved by a nurse-monitored structured care program? A randomized controlled trial. Heart Lung. 2003;32(1):3-9. [pmid: 12571543].
25 Giordano A, Scalvini S, Zanelli E, et al. Multicenter randomised trial on home-based telemanagement to prevent hospital readmission of patients with chronic heart failure. Int J Cardiol. 2009;131(2):192-9. [pmid: 18222552].
26 Krantz MJ, Havranek EP, Haynes DK, et al. Inpatient initiation of beta-blockade plus nurse management in vulnerable heart failure patients: a randomized study. J Card Fail. 2008;14(4):303-9. [pmid: 18474343].
27 Mejhert M, Kahan T, Persson H, et al. Limited long term effects of a management programme for heart failure. Heart. 2004;90(9):1010-5. [pmid: 15310688].
28 Sisk JE, Hebert PL, Horowitz CR, et al. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. Ann Intern Med. 2006;145(4):273-83. [pmid: 16908918].
29 Stromberg A, Martensson J, Fridlund B, et al. Nurse-led heart failure clinics improve survival and self-care behaviour in patients with heart failure: results from a prospective, randomised trial. Eur Heart J. 2003;24(11):1014-23. [pmid: 12788301].
30 Thompson DR, Roebuck A, Stewart S. Effects of a nurse-led, clinic and home-based intervention on recurrent hospital use in chronic heart failure. Eur J Heart Fail. 2005;7(3):377-84. [pmid: 15718178].
31 Dorr DA, Wilcox AB, Brunker CP, et al. The effect of technology-supported, multidisease care management on the mortality and hospitalization of seniors. J Am Geriatr Soc. 2008;56(12):2195-202. [pmid: 19093919].