# PEER REVIEW COMMENTS

Reviewer | Comment | Response
Question 1: Are the objectives, scope, and methods for this review clearly described?
1 | Yes. I appreciated the focused and concise research questions that guided this review. The inclusion and exclusion criteria are well stated and the search was comprehensive in accordance with the design. The review process was thorough in all aspects, with sufficient narrative to support findings, data synthesis, and risk of bias and strength of evidence. As a reviewer, the careful attention to these details gave me confidence in the objectivity of the study and in the results. | Thank you.
2 | Yes. No comments | Acknowledged
3 | Yes. No comments | Acknowledged
4 | No. No comments | Acknowledged
5 | Yes. No comments | Acknowledged
6 | Yes. No comments | Acknowledged
7 | Yes. The overall scope of this project is to improve the care of patients with select chronic conditions (hypertension, hyperglycemia, hyperlipidemia, and congestive heart failure); the mechanism selected to achieve this goal is to expand the role of the nurse within the PACT by using nurse-managed protocols. The objectives, scope and methods are clearly described. However, it remains unclear as to how the inclusion and exclusion criteria were determined for the intervention studied. That limiting the study selection to protocols involving medication adjustment may enhance the validity and generalizability of the project is acknowledged. Nonetheless, given the complexity of chronic illness, multiple approaches are likely needed to achieve positive outcomes. Thus it would be beneficial for the reader to better understand why educational interventions and therapy evaluation studies were excluded, as these interventions can also be useful in the management of chronic illness. | Thank you for the thorough comment. We agree that educational and therapy interventions are important in the management of chronic illness, and multiple systematic reviews have described this literature. Our stakeholders were interested in studies where nurses practiced beyond their typical scope of practice (e.g., medication titration). Thus, we included studies that required the nurse to have the ability to practice beyond their scope of practice and have at a minimum the autonomy to titrate/adjust medication. Studies were not excluded if they had an educational or therapy component but were required to also have this medication titration component.
7 | Finally, the rationale for using nurse satisfaction as an inclusion criterion is missing and could be a useful addition. | Nurse satisfaction was not an inclusion criteria but part of Key Question 1 to examine the effects of nurse-managed protocols. Otherwise eligible studies that reported any of the relevant outcomes (including nurse satisfaction) were included.
8 | No. Overall, this is a very well done evidence synthesis in a complicated area. There are a few areas where additional clarification is needed regarding the objectives, scope, and methods.
8 | 1) Better clarification is needed regarding how “nurse” is defined in this synthesis and the generalizability of findings to different types of nurses. Throughout the report, terms such as “non-NP nurses”, “nurse-managed protocols”, “RN and LPN”, and “RN-based protocol interventions” are used. Each of these terms defines nurses differently. The inclusion/exclusion criteria state that the intervention had to involve an RN or LPN functioning beyond the usual scope of practice, but then later on we see that only RNs were included in the studies in the evidence base. The generalizability of the evidence base only to RNs should be made earlier on in the report. A stronger statement is also warranted in the conclusion noting that there was no evidence specifically examining the role of the LPN in nurse-managed protocols and the implications of this if considering expanding nurse-managed protocols for LPNs. | 1) Thank you for the comment. We have made terminology for nurse more consistent throughout the manuscript. We have also specified that no studies reported using LPNs as nurse interventionists and have made a stronger statement in the discussion that there is no evidence specifically examining the role of the LPN.
8 | 2) Additional clarification is also needed in the introduction section regarding nurse-managed protocols. A more formal definition and history/background of these protocols would be helpful to the reader in understanding the scope. While it is acknowledged that there are many variations on what this protocol entails, in its current form, it is left up to the reader to determine the definition based on the inclusion/exclusion criteria, description of the included articles, etc. Similarly, it is unclear why adjustment of medications is the only component of the nurse-managed protocol that was required as part of the inclusion criteria. Additional background on nurse-managed protocols may help clarify this. | 2) We agree with the reviewer and have added a brief discussion of how protocols began in nursing and also provided a definition of protocol. We have further specified that these studies were limited to those that required the nurse to have the ability to practice beyond their scope of practice and have at a minimum the autonomy to titrate/adjust medication.
8 | 3) Risk of Bias (Quality) and Strength of Evidence Assessment section discusses criteria for observational studies; however, key eligibility criteria include randomized controlled trial or quasi-experimental study. Clarification is needed for this discrepancy. | 3) We included RCTs and quasi-experimental studies. In the section, “Risk of Bias (Quality) Assessment” we give major criteria for RCTs and quasi-experimental (observational) studies.
9 | Yes. Objectives, scope and methods were described clearly, see p. 11 | Thank you.
Question 2: Is there any indication of bias in our synthesis of the evidence?
1 | No. As noted above, the team was fully engaged in conducting a detailed and thorough review and used processes to mitigate bias to the extent humanly possible. The narrative supports these efforts in process and in research study review. | Acknowledged
2 | No. Very clear discussion on Bias concerns of the reviewed studies | Thank you.
3 | No. No comments | Acknowledged
4 | No. No comments | Acknowledged
5 | No. No comments | Acknowledged
6 | No. No comments | Acknowledged
7 | Yes. The risk of bias was carefully addressed overall. However, one area that can potentially bias the findings and the applicability to the PACT setting lies in the lack of a consistent definition of the term, “nurse” and “nurse training” (e.g., Tables 3 & 4). The type and role of the nurse was not well defined in the studies used for this evidence synthesis. For example, many of the studies were conducted in the U.K., using “specialist” nurses. The UKCC definition of specialist nurse in the UK appears more closely resembling that of the clinical nurse specialist in the U.S. than that of the registered nurse (see Standards for Specialist Education and Practice1). Other roles included certified diabetes educator (e.g., papers authored by Philis-Tsimikas, Aubert, Houweling,), “nurse specialist” in a particular disease, such as diabetes or CHF (e.g., papers by MacMahon Tone, O'Hare, Bellary, Wallymahmed, Berger), or “case manager” (e.g., papers by DeBusk, DeBusk); a rapid review of these papers did not find thorough descriptions of these roles nor of the educational preparation needed to qualify for such roles. | Thank you for the comment. We have made terminology for nurse more consistent throughout the manuscript. We have also specified that no studies reported using LPNs as nurse interventionists and have made a stronger statement in the discussion that there is no evidence specifically examining the role of the LPN. We have also added detail in Tables 4 and 5 (formerly Tables 3 and 4) under nurse training. Furthermore, we have included an appendix and additional description about querying authors when we were unsure of the educational role of the nurse. Authors for all included studies responded that the nurse interventionists used were a U.S.-equivalent RN.
7 | Caution should be emphasized when generalizing these interventions to settings using nurses without such educational preparation and experience, and warrants more careful discussion early in the review. This concern is partially addressed in the clinical implications section (page 42), but given the importance, it warrants inclusion in the section describing the interventions (Tables 3 & 4), as well as in the executive summary. Perhaps additional information related to the role of the nurse in question and relevant educational preparation was obtained during the investigators' author query; if so, further delineation of role and educational preparation/training would help the reader. | Details on the education and preparation needed for a nurse to assume a responsibility to titrate medications is a gap in the literature (Table 2), noted as a limitation, and further research is warranted. We have added a key point to the executive summary that educational preparation was not well reported.
8 | No. No comments | Acknowledged
9 | No. Multiple sources of bias in the STUDIES reviewed were addressed and considered in the interpretation of the findings | Acknowledged
Question 3: Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
1 | No. The dominance of physician's leading all aspects of the health team through medical orders is not a surprise; it is surprising that there is so little in the research literature to support the autonomous contributions of other health professionals who spend considerably more time with patients. Given the era of evidenced-based practice, which grew out of care maps and other designs to manage patient care on a specified trajectory, it is equally distressing that the resources expended on those efforts has not been captured in the literature. My strong sense is that you have captured the state-of-research for these common health conditions. | Acknowledged
2 | No. I am aware that Portland VA Medical Center initiated some Nurse Run Protocols for initiation of insulin management and also hypertension. I do not know if there was any intent to publish as the protocols were not subject to the research disclaimers typically communicated. | Acknowledged
3 | Yes. Comments: Watts, SA, Lawrence, RH, & Kern, E. (2011). Diabetes nurse care manager training program: enhanced care consistent with the chronic care and patient-centered medical home models. Clinical Diabetes, 29, 25–33. This VHA study found positive effects of nurses using diabetes protocols. This study addresses both the educational requirements for nurses as well as describing nurse satisfaction outcomes. | Thank you. We have added this study to the literature search numbers and added it to the discussion. This article by Watts, et al. (2011) will be quite useful as an exemplar for intervention descriptions, but it was not included in the report except in the Discussion as it did not meet the Cochrane EPOC Guidelines for study designs.
4 | No. Not aware of any. | Acknowledged
5 | No. No comments | Acknowledged
6 | No. No comments | Acknowledged
7 | No. A quick literature review did not reveal any substantive additional studies overlooked in this synthesis. | Acknowledged
8 | No. No comments | Acknowledged
9 | No. I am not aware of any that were omitted | Acknowledged
Question 4: Please write additional suggestions or comments below. If applicable, please indicate the page and line numbers from the draft report.
1 | The VA – especially through the PACT model – should advance the role of nurses and other health professionals who are relevant to population health needs. The Advanced Practice Nurse who is prepared as a practice scholar (DNP) or a research scholar (PhD) is in the strongest position to develop, implement, and evaluate clinical protocols. These protocols should be evidence-driven and intersect with standard medical protocols for disease management. Nursing protocols should reflect the practice of nursing in that individual, family, and environmental/community needs should be included as part of a holistic approach. Behavioral protocols, reinforcement and motivation, and environmental adaptations should be clearly stated in interventional terms. The use of Registered Nurses to implement and evaluate approved protocols should be done once an assessment is made of the RNs clinical knowledge, decision-making confidence and adaptability, communication capacity (verbal and written) with patients, families, and health team members, and their capacity to be accountable. A well-rounded professional nurse will possess these qualities, but not all nurses possess these traits; some are most comfortable in a role where they are directed. Based on the review of the literature and the complexity of decision-science demanded to operate under protocol (regardless of how detailed), I would cautiously proceed with the use of an LPN in this role. | Thank you for this thorough comment. We agree that a well-rounded professional nurse will possess all the qualities to safely use nurse-managed protocols. However, because the studies included in this review did not use LPNs, we can only generalize the findings to that of the RN. We agree that further research is warranted as to the use of LPNs. We have added additional details regarding the need for more information on the clinical knowledge, decisionmaking confidence, and communication capacity needed for a nurse in this role.
2 | Appendix D, Page 65, took a while to find the explanations for the NLC and DMP abbreviations. | We have spelled out those terms (nurse-led clinic and disease management program) in the table cells. That table is now in Appendix F.
3 | No comments | Acknowledged
4 | No comments | Acknowledged
5 | “All 29 studies required the nurse to have the autonomy to titrate medications; however, only 20 reported that the nurse was allowed to independently initiate a new medication.” This review is excellent. Just one comment. I wonder about the use of the word “only” in the quote above. It implies that 20 is small portion but in fact it is actually 2/3rds of the sample. This is a small point but in our organization it has been extremely hard to get any action on this important health care delivery strategy. I would prefer to avoid any argument for those who find it hard to imagine using our excellent nursing colleagues in this way. | We have rewritten this section to simply describe that 20 of the 29 studies allowed the nurse to also prescribe medications in addition to titration.
6 | No comments | Acknowledged
7 | PACT embraces the concept of “team”. The authors acknowledge the importance of the role of specific team members – physicians, nurse practitioners, physician assistants, and nurses (pg 43). The role of the LPN does not appear to fit within the body of evidence presented and warrants further description as to how the LPN role might still be utilized within the PACT model outside the scope of using nurse-managed protocols (pg 43). Clarifying what is meant by “nurses”, including other nursing roles, such as the clinical nurse specialist and expanded-role registered nurse, would strengthen this comprehensive, high-quality evidence synthesis summary. | We have provided more detail that while our initial search included the use of LPNs, no studies used an LPN as the nurse interventionist. We generalize the findings to the RN and recognize that the absence of studies utilizing LPNs is a limitation of this review and warrants further research.
8 | 1) Page 23, first line in last paragraph under Treatment Adherence, it states “Among the studies that reported treatment adherence to medication”; however, earlier it was stated that only one study reported treatment adherence to medication. This inconsistency should be revised. | Thank you noticing this. We have amended this inconsistency.
8 | 2) Not sure I agree with the conclusion that “Nurse-managed protocols may be most effective for managing illnesses where self-management and patient adherence to medications is needed,” (pg. 8 and 44). Only one study directly examined patient adherence to medications; therefore, further support is needed to justify this conclusion. | We have revised this section to focus on using nurse-managed protocols where a nurse could titrate or prescribe important and frequently used medications for diseases such as diabetes where medication titration and self-management are both key.
9 | No comments. | Acknowledged
Optional Dissemination and Implementation Questions
Question 5: Are there any clinical performance measures, programs, quality improvement measures, patient care services, or conferences that will be directly affected by this report? If so, please provide detail.
1 | I believe this report could make a major contribution related to the IOM report, The Future of Nursing: Leading Change, Advancing Health and the Robert Wood Johnson Campaign for Action that is implementing major components of the IOM report. This report is germane to several key aspects of the report findings: expanded scope of practice, leadership development, testing new models of care, lifelong learning and expanding nurse competencies to meet the emerging public demands for access to care. Further, the implications for the process of developing nurses to assume expanded responsibilities should be observed and evaluated for sharing throughout the nursing community. There are many organizations who would benefit from the PACT model (I see this as part of model development) as the VA has defined the elements of the medical home. | Thank you.
2 | Performance Measures exist for Diabetes Hemoglobin A1C > 9% or not done within a year, Cholesterol control in patients with Diabetes or Ischemic Heart disease, as well as hypertension. The hope is that appropriate Nurse run protocols can show improvement in these areas. | Acknowledged
3 | Yes. The Office of Nursing Services is currently conducting several nurse protocol pilot programs in order to gather information to form national guidance. This report will be utilized in the formation of the national guidance | Acknowledged
4 | No comments | Acknowledged
5 | Absolutely, it provides the evidence to support revolutionizing how health care is delivered in the VA and will enable us to transform how care is delivered at every level of the organization. There will be no clinical service untouched. | Acknowledged
6 | This will enhance our understanding and support utilization of nurse-managed protocols in PACT as well as specialty care transformation. | Acknowledged
7 | Performance measures are currently described within this report as is PACT. | Acknowledged
8 | No comments | Acknowledged
9 | This review should inform the efforts in PACT to encourage nursing practice at the highest level of licensure. The data reviewed here also suggest some additional studies that would be appropriate to implement across sites using PACT, including the Centers of Excellence in Primary Care Education. | Acknowledged
Question 6: Please provide any recommendations on how this report can be revised to more directly address or assist implementation needs.
1 | The question remains as to what a nurse-managed protocol looks like: how is it different than standing orders? How is it different from a care map? Is it designed to allow autonomy, or is it algorhymic in nature to avoid risk and to “catch” potentially weaker nurses by guiding them to a desired set of activities? This work should be done prior to implementation, or it will confound point-of-care providers as just another tool. So, it should LOOK different than other existing tools, should be LIMITED in scope to clinical conditions, and it must complement the reality that no patient has JUST one “chronic” medical condition – so the judgment tied to its use must place it within the context of the WHOLE patient medical portfolio of concerns. | We agree. There are a lot of details about nurse-managed protocols that are needed for next steps and implementation. Further investigation and translational research are needed.
2 | If there are any hyperlinks to the study report themselves it would simplify getting more detail on what the specific protocols initiated were. | This is a good suggestion. Currently our reports are available only in pdf format, but we will pass the comment along to the ESP coordinating office.
3 | Know the components that led to a successful intervention – such as hours and content of training, use of electronic medical record decision support, the development of clinical competency for evaluation. | We have included this information as recommendations for future research.
4 | I thought that the satisfaction of the nursing staff listed first did not reflect a patient centered approach | Thank you for the comment. We agree that nurse satisfaction, while an important outcome, is not a patient-centered outcome. However, we present the results in the order listed in the Key Questions. Our executive summary, key points, and strength of evidence table focus on patient-centered and important biophysical outcomes.
5 | See my comment in question # 4 above.
5 | “This may be particularly useful for diseases such as diabetes that have a preclinical phase in which the risk of complication is relatively high, or where medication titration and self-management are key to adequate management but symptoms are minimal or not yet clinically serious” I think this statement is speculative. We should stick to the evidence. My worry is that the elements in the VA who have been resisting this advance will latch on to this statement and slow our progress especially for those patients who are further along their disease progression and could therefore benefit in the short run. My recommendation would be eliminate this statement all together unless there is strong evidence that this is the only group where nurse protocols are effective. | Thank you. We have reworded this statement and moved away from the speculative phrasing.
6 | Effective communication of the report findings will be valuable for facilitating implementation. | Acknowledged
7 | See comments above for suggestions. | Acknowledged
8 | No comments | Acknowledged
9 | Implementation of some of the protocols that were assessed in the studies reviewed would be facilitated by identification of links to the protocols, themselves, as well as translational work to be conducted within the VA sites, e.g. PACT and COE PCE sites | We agree. However, studies typically cited a guideline and gave only summary information about protocols. As part of our author queries, we requested copies of the protocol but the protocol was only provided by a single author. We highlighted the study by Watts et al. (2011), which gives detailed information about the protocol.
Question 7: Please provide us with contact details of any additional individuals/stakeholders who should be made aware of this report.
1 | Susan Hassmiller, RWJ Project Director – Campaign for Action; Mary Naylor – University of Pennsylvania – whose work with the transitional care model may be of assistance. Kathy Apple and Dr. Franklin Shaffer, with the National Council of State Boards of Nursing and Council on Graduates of Foreign Schools of Nursing, respectively, to guide their work. | Acknowledged
2 | Dr. David Macpherson involved with Primary Care Field Advisory Committee. David.Macpherson@va.gov | Acknowledged
3 | ONS will want to distribute this widely. PCS, including PACT, Specialty care and PBM should be made aware of the report | Acknowledged
4 | Tri Council members, Diane Mancino, Debra Barksdale | Acknowledged
5 | I think nursing service will be very receptive to these findings. Our greatest challenge will be with the specialty community and especially the specialist from a prior generation and/or who have not worked outside the VA. I would spend some informal time with the leaders of specialty care operations to solicit their support before distributing this review widely. | Acknowledged
6 | In addition to PACT/Primary Care and Nursing, would also involve Specialty Care and Geriatrics. | Acknowledged
7 | Marthe Mosley, PhD, RN, CCNS, Associate Director, Clinical Practice; Christine Engstrom, PhD, CRNP, Director, Clinical Practice, Storm Morgan, BSN, RN, MBA, ONS PACT Program Manager; Office of Nursing Service, Field Advisory Committees (cardiovascular, diabetes/metabolic) | Acknowledged
8 | No comments | Acknowledged
9 | This is a timely and important study that should be circulated widely within and outside of the VA. Many of the protocols that were tested would most likely be appropriate for implementation within the Federally Qualified Health Centers and Nurse Managed Clinics, both of which have organizational structures to facilitate exchanges of information and findings in this report. | Acknowledged