# CRITERIA USED IN RISK OF BIAS ASSESSMENT

## I Guidance on Assessing Risk of Bias for Randomized Controlled Trials

General instructions: (1) Rate each risk of bias item listed below as Low risk/ High risk/ Unclear risk (refer to Cochrane guidance to inform judgements). Add comments to justify ratings. (2) After considering each quality item, give the study an overall rating of “Low risk,” “Moderate risk,” or “High risk” (see below).

### Rating of individual items

1. Selection bias:
  a. *[underlined: Randomization adequate] (Adequate methods include random number table, computer-generated randomization, minimization without a random element.) Low risk/ High risk/ Unclear risk
    * Indicates items contained in Cochrane Risk of Bias Tool.
  b. *[underlined: Allocation concealment] (Adequate methods include pharmacy-controlled randomization, numbered sealed envelopes, central allocation.) Low risk/ High risk/ Unclear risk
  c. [underlined: Baseline characteristics] (Consider whether there were systematic differences observed in baseline characteristics and prognostic factors between groups, and if important differences were observed, if the analyses controlled for these differences.) Low risk/ High risk/ Unclear risk
2. Performance bias:
  a. *[underlined: Concurrent interventions or unintended exposures] (Consider concurrent intervention or an unintended exposure (e.g., crossovers; contamination – some control group gets the intervention) that might bias results) Low risk/ High risk/ Unclear risk
  b. [underlined: Protocol variation] (Consider whether variation from the protocol compromised the conclusions of the study.) Low risk/ High risk/ Unclear risk
3. Detection bias:
  a. *[underlined: Subjects blinded] (Consider measures used to blind subjects to treatment assignment and any data presented on effectiveness of these measures.) Low risk/ High risk/ Unclear risk
  b. [underlined: *Outcome assessors blinded, hard outcomes] (Outcome assessors blind to treatment assignment for “hard outcomes” such as mortality.) Low risk/ High risk/ Unclear risk
  c. [underlined: *Outcome assessors blinded, soft outcomes] (Outcome assessors blind to treatment assignment for “soft outcomes” such as symptoms.) Low risk/ High risk/ Unclear risk
  d. [underlined: Measurement bias] (Reliability and validity of measures used.) Low risk/ High risk/ Unclear risk
4. Attrition bias:
  a. [underlined: *Incomplete outcome data] (Consider whether incomplete outcome data were adequately addressed, including systematic differences in attrition between groups [differential attrition]; overall loss to followup [overall attrition]; and whether an “intention-to-treat” [ITT; all eligible patients that were randomized are included in analysis] analysis was performed.) (Note: mixed models and survival analyses are, in general, ITT.) Low risk/ High risk/ Unclear risk
5. Reporting bias:
  a. [underlined: *Selective outcomes reporting] (Consider whether there is any suggestion of selective outcome reporting; e.g., systematic differences between planned and reported findings.) Low risk/ High risk/ Unclear risk

### Overall study rating

Please assign each study an overall quality rating of “Low risk,” “High risk,” or “Unclear risk” based on the following definitions:

- A “Low risk” study has the least bias, and results are considered valid. A low risk study uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results. [Items 1a and 1c; 2a; 3b and 3c; and 4a are all rated low risk.]
- A “Moderate risk” study is susceptible to some bias but probably not enough to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems (unclear risk). As the moderate risk category is broad, studies with this rating vary in their strengths and weaknesses. [Most, but not all of the following items are rated low risk: Items 1a and 1c; 2a; 3b and 3c; and 4a.]
- A “High risk” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a high risk study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions. [At least one-half of the individual quality items are rated high risk or unclear risk]

### Conflict of interest (recorded but not used as part of Risk of Bias Assessment)

Was there the absence of potential important conflict of interest? The focus here is financial conflict of interest. If no financial conflict of interest (e.g., if funded by government or foundation and authors do not have financial relationships with drug/device manufacturer), then answer “Yes.” Yes /No /Unclear

## II Guidance on Assessing Risk of Bias for Nonrandomized Studies