# SAMPLE AUTHOR QUERY LETTER

Dear Dr. INSERT LAST NAME:

We are conducting a systematic review on nurse-led interventions and are writing in regards to your paper, “INSERT TITLE.” To be eligible for our study, a) the intervention must utilize a nurse with similar training to a registered nurse or licensed practical nurse in the U.S.A. and b) the nurse must use a protocol to initiate or adjust one or more medications. Our preliminary review suggests your study is eligible for our review, but we require clarification about details of the intervention to make a final eligibility determination. Please answer the following:

1. Did the nurse(s) utilized in your study have similar educational training, credentials, or scope of practice to a Registered Nurse (RN) or Licensed Practical Nurse (LPN/LVN)? (see definitions below)
  a. Yes, similar to an RN or LPN
  b. Yes, similar to an RN or LPN but with the following important differences:__________
  c. No, not similar (e.g., equivalent to a U.S.A trained Advanced Practice Nurse)
2. Did the nurse use a protocol or algorithm to guide practice?
  a. Yes (We will appreciate if you share a copy of your nurse protocol. Please send by email)
  b. No
3. Did the nurse have decision making authority to initiate or adjust medications as specified in a protocol or algorithm?
  a. Yes, decision making authority
  b. No, the nurse did not initiate or adjust medications.
4. Additional clarification: (optional if other information is needed)

We sincerely appreciate your response to this query,

John W. Williams, MD, and Ryan Shaw, PhD, RN, for the Durham Evidence Synthesis Team

Description of RN or LPNs trained in U.S.A. (ELIGIBLE for our study) | Description of Advanced Nurse Practitioners (NOT ELIGIBLE for our study)
Education/training:; - Diploma from a nursing school or hospital; - Associate's degree in nursing (2-year degree); - Bachelor's degree in nursing (4-year degree) | Education/training:; - Master's degree in nursing; - Doctoral degree in nursing
Credentialing and Scope of Practice:; - Educates patients, families, and communities on conditions and treatment plans; - Assists and supports patients, families, and communities in performing lifestyle modifications; - Provides emotional support to patients and their family; - Monitors response to medical treatment plans; - Administers medications and vaccinations; - Monitors treatment adherence including medication compliance; - Performs medication reconciliation; - Helps perform diagnostic tests and analyzes results (i.e., blood sugar values and urine dipsticks); - Performs physical assessments including vital signs | Credentialing and Scope of Practice includes the RN/LPN scope of practice and in addition:; - Prescribes medication and treatment; - Orders and interprets diagnostic tests; - Performs or assists in minor surgeries or procedures (e.g., biopsies, suturing, casting); - Can serve as a primary care provider; - Includes nurse midwives, nurse anesthetists, clinical nurse specialists