# SEARCH STRATEGIES

Table A-1 Search strategy for PubMed (December 12, 2012)

Set # | Terms | Results
1 | “Nurse's Role”[Mesh] OR “Nursing Process”[Mesh] OR “Nursing Staff”[Mesh:noexp]) OR (nurse[tiab] OR nursing[tiab] OR nurses[tiab] | 351362
2 | (nurse[tiab] OR nursing[tiab] OR nurses[tiab]) AND (driven[tiab] OR intervention[tiab] OR interventions[tiab] OR managed[tiab] OR run[tiab] OR led[tiab] OR implemented[tiab] OR clinic[tiab] OR clinics[tiab]) | 43427
3 | (nurse[tiab] OR nursing[tiab] OR nurses[tiab]) AND (“Diagnostic Tests, Routine”[Mesh] OR “Medication Therapy Management”[Mesh] OR “Referral and Consultation”[Mesh]) | 3585
4 | (nurse[tiab] OR nursing[tiab] OR nurses[tiab]) AND (medication[tiab] OR drug[tiab] OR drugs[tiab]) AND (adjust[tiab] OR adjustment[tiab] OR manage[tiab] OR management[tiab] OR titrate[tiab] OR titration[tiab] OR prescribe[tiab] OR prescribing[tiab] OR initiate[tiab]) | 4080
5 | (nurse[tiab] OR nursing[tiab] OR nurses[tiab]) AND ((order[tiab] OR ordered[tiab] OR ordering[tiab]) AND (diagnostic[tiab] OR test[tiab] OR tests[tiab])) | 1168
6 | #2 OR #3 OR #4 OR #5 | 48849
7 | “Hypertension”[Mesh] OR “Diabetes Mellitus”[Mesh] OR “Heart Failure”[Mesh] OR Hyperlipidemia[MeSH] OR Hypertension[tiab] OR Diabetes Mellitus[tiab] OR Heart Failure[tiab] OR hyperlipidemia[tiab] | 764735
8 | #1 AND #6 AND #7 | 2884
9 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR drug therapy[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] OR Clinical trial[pt] OR “clinical trial”[tw] OR “clinical trials”[tw] OR “evaluation studies”[Publication Type] OR “evaluation studies as topic”[MeSH Terms] OR “evaluation study”[tw] OR evaluation studies[tw] OR “intervention studies”[MeSH Terms] OR “intervention study”[tw] OR “intervention studies”[tw] OR “cohort studies”[MeSH Terms] OR cohort[tw] OR “longitudinal studies”[MeSH Terms] OR “longitudinal”[tw] OR longitudinally[tw] OR “prospective”[tw] OR prospectively[tw] OR “follow up”[tw] OR “comparative study”[Publication Type] OR “comparative study”[tw] OR systematic[subset] OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[tw] OR “meta-analyses”[tw]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp]) NOT (animals[mh] NOT humans[mh]) | 4558979
10 | “pre-post”[tiab] OR prepost[tiab] OR “post-test”[tiab] OR posttest[tiab] OR pretest[tiab] OR pre-test[tiab] OR quasi-experiment*[tiab] OR quasiexperiment*[tiab] OR quasirandom*[tiab] OR quasi-random*[tiab] OR quasi-control*[tiab] OR quasicontrol*[tiab] OR (“time-series”[tiab] AND interrupt[tiab]) OR (“time-points”[tiab] AND (multiple[tiab] OR one[tiab] OR two[tiab] OR three[tiab] OR four[tiab] OR fve[tiab] OR six[tiab] OR seven[tiab] OR eight[tiab] OR nine[tiab] OR ten[tiab] OR month*[tiab] OR day[tiab] OR days[tiab] OR week*[tiab] OR hour*[tiab]) OR (before[tiab] AND after[tiab]) OR (*before[tiab] AND during[tiab])) | 56936
11 | (#8 AND (#9 OR #10) Publication date from 1980/01/01 to 2012/12/31, English | 1822