# Addendum to “Effects of Nurse-Managed Protocols in the Outpatient Management of Adults with Chronic Conditions: A Systematic Review and Meta-analysis”

## Reanalysis of CVD-related Data

Prepared by Jennifer McDuffie, Andrzej Kosinski, Ryan Shaw, John Williams

Our report, “Effects of Nurse-Managed Protocols in the Outpatient Management of Adults with Chronic Conditions: A Systematic Review and Meta-analysis,” was submitted to the Annals of Internal Medicine for publication.

After this report was completed and published, the statistical reviewer for a journal submission requested that we reanalyze the data using a statistical approach that accounted for small numbers of studies.

In response to this recommendation, we reanalyzed the data using the Knapp and Hartung (2003) method to adjust the standard errors of the estimated coefficients to help to account for the uncertainty in the estimate of the amount of (residual) heterogeneity. As expected, this analyses did not change any of the point estimates , but 95% confidence intervals increased for some of the outcomes. The original summary estimates of effect and the revised estimates of effect are summarized in the table below.

Table of original vs. revised Confidence Intervals

Statistic (direction of comparison: RNP vs. UC) | Original summary estimates (95% CI) | Revised summary estimates (95% CI_
Mean difference in HbA1c | -0.40 (-0.63 to -0.17) | -0.40 (-0.70 to -0.10)
(non-RCTs) | -1.12 (-2.99 to 0.74)
Mean difference in SBP | -3.68 (-5.67 to -1.69) | -3.68 (-6.31 to -1.05)
Mean difference in DBP | -1.56 (-2.57 to -0.55) | -1.56 (-2.76 to -0.36)
Achieve target BP values vs. controls (OR) | 1.41 (1.21 to 1.78) | 1.41 (0.98 to 2.02)
Mean difference in total cholesterol (mmol/L) | -0.24 (-0.46 to 0.02) | -0.24 (-0.54 to 0.05)
Mean difference in low-density-lipoprotein cholesterol | -0.31 (-0.62 to 0.00) | -0.31 (-0.73 to 0.11)
Achieve target TC values vs. controls (OR) | 1.54 (1.14 to 2.08) | 1.54 (1.02 to 2.31)

OR = Odds ratio

Reference: Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Statistics in Medicine. 2003;22:2693-2710. [pmid: 12939780]. .