# SUMMARY AND DISCUSSION

## SUMMARY AND DISCUSSION

The key observation that emerges from review of the literature is that current evidence examining the effect of psychotherapy as augmentation or substitute therapy in resistant depression is sparse and reveals mixed results. Of the six studies reviewed, four studies examined psychotherapy as augmentation to antidepressant treatment37, 40–42 and two studies examined psychotherapy as substitution treatment.37, 49 The STAR*D trial reflects the greatest ecological validity of the studies reviewed, because it accounted for patient preference in randomization and is most reflective of treatment provided in primary care settings. One study suggested that psychotherapy used as augmentation had better impact on clinical symptoms of MDD than medication alone41 whereas Kennedy et al. found the opposite effect.42 The remaining studies did not detect any difference between psychotherapy augmentation and continuation on antidepressant treatment.37, 40 Substitution of antidepressant therapy with psychotherapy appeared to have the same benefit as substituting another antidepressant37 or continuing previous medication.49 While each of the studies included in this review addressed at least a portion of the initial key research question, none of the studies provides a complete answer to the initial question nor does an amalgamated consideration of the studies provide an entirely sufficient answer to the initial question. Most studies appeared to be underpowered to detect moderately large treatment effects, and conclusions are tempered by the heterogeneity in study designs and patient populations and limited number of good quality trials. We conclude that although current trials do not support favoring psychotherapy over antidepressant medication for mid-life adults with treatment resistant MDD, psychotherapy appears to be an equally effective treatment compared to antidepressant medication and is therefore a reasonable treatment option for this demographic. Whether these results are directly applicable to Veterans is uncertain. Veterans are on average older and have high rates of psychiatric and medical co-morbidity, clinical characteristics that were not well described in the studies reviewed.

Treatment via psychotherapy continues to face numerous barriers both in primary care and specialty mental health settings. The first consideration is access to psychotherapy. Many Veterans live in underserved areas and may have to travel farther to access facilities that would offer psychotherapeutic interventions. This issue is exacerbated by the greater time commitment required to receive traditional psychotherapy, which often requires weekly or biweekly face-to-face contact for an hour each. A second consideration is the relative cost of delivering psychotherapy versus providing antidepressant medications. The baseline costs of psychotherapy are typically higher, especially when delivered by a mental health professional such as a psychologist.50, 51 However, there appears to be dispute when mid to long-term outcomes are measured. Some studies have demonstrated that antidepressant medications are more cost-effective within 1 year of follow-up for both direct and indirect costs.52, 53, whereas other studies have not found differences in direct, aggregate or societal costs.51, 54, 55 Studies have found psychotherapy to be superior in reducing costs related to missed work 56, treatment of medical comorbidities57, and relapse.45 Therefore, the cost-benefit ratio of antidepressant treatment versus psychotherapy remains disputed. A further limitation is that no current study has examined the cost-effectiveness of the two treatments in patients who do not respond to initial antidepressant treatment. Because TRD is both common and costly58, large, high quality, long-term randomized trials are needed to evaluate the effectiveness and cost-effectiveness of different treatment strategies for patients with TRD.

One strategy to increase access and cost-effectiveness of psychotherapy involves collaborative care. Recent research has shown that training non-mental health professionals (e.g., nurses) to provide brief psychotherapeutic interventions are effective in reducing depressive symptoms.59–61 Collaborative care models involving depression care managers has been shown to improve the quality of depression care, symptom severity, patient satisfaction, and functional impairment.50,62 Some of these trials59, 63 utilized empirically based psychotherapy as a step-2 treatment option for treatment resistant patients. These studies were conducted in older adults with MDD or dysthymia who are more similar to the Veteran population than most of the studies we reviewed in the current evidence synthesis. Unfortunately, the psychotherapy was delivered as part of a package of collaborative care and its unique contribution to improved outcomes cannot be assessed. Nevertheless, evidence suggests that training non-mental health professionals to deliver brief psychotherapy may improve outcomes in primary care patients without burdening resources within the VA system.

Prior systematic reviews 19–23 have shown that psychotherapy and antidepressant medications have similar benefit in acute phase treatment for MDD. For patients with chronic MDD or dysthymia, current evidence supports the combination of psychotherapy and antidepressant medication for initial treatment. Treatment resistant depression is common and a greater number of effective treatment options are needed. Our evidence synthesis found only limited studies that do not support psychotherapy as a step-2 strategy, either for augmentation or as a substitute for antidepressant medication.

## LIMITATIONS

Several limitations of the current literature emerged upon review. First, few RCTs exist that adequately address the question of resistant depression. In the future, this may be addressed in two ways: 1) re-analysis of existing data from trials in which patients with TRD are recruited, or 2) conducting studies designed to examine this question. Second, there was significant heterogeneity in how resistant depression was defined in the different studies. Measures included interviewer rated depression scales (e.g., HAM-D), self-report depression scales (e.g., BDI), DSM diagnostic criteria (DSM-III-R or DSM-IV), and clinical judgment. Future studies should consider a standardized operational definition of TRD to facilitate comparisons across studies. Third, all of the studies involved comparators that received active treatment. True placebo controlled trials may be necessary to compare the relative effects of psychotherapy and antidepressants as second step treatments. Fourth, none of the six studies reviewed involved patients from within the VA. Compared to the general population, Veterans have higher incidences of depression with psychiatric and medical comorbidities.4 Therefore, results of the current review may have limited generalizability to the VA population. Fifth, only two psychotherapeutic strategies have been considered in the limited literature, with the majority using CT. Traditionally, CT requires a minimum of 12–16 sessions and is often delivered by trained experts. As a result, none of the psychotherapies reviewed were likely to be administered within the primary care setting. This is in contrast with the larger literature, where brief therapies such as problem-solving therapy and interpersonal therapy have been adapted by non-mental health professionals with demonstrated improvements as first step treatments in primary care settings.50 Studies to compare the effectiveness of differing psychotherapies could inform policy.