# RESULTS

## LITERATURE FLOW

Using the search strategy described in Appendix A, 41 systematic reviews were identified, of which 29 were excluded at the title and abstract level and the remaining 12 were excluded after conducting a full-text review (Figure 1). Reviews were excluded primarily because they did not apply to the question we were addressing or were not systematic; therefore, no systematic reviews were included in this report.

Figure 1 Systematic Reviews Literature Flow

Next, we searched for relevant randomized clinical trials. Using the search strategy described in Appendix B, 333 randomized clinical trials were identified for review. Of these, 290 were excluded at the title and abstract level, and 43 were selected for full text review. Thirty-one articles were excluded following full-text review, yielding 12 articles for inclusion (Figure 2). These 12 articles represent five unique studies, of which one of the studies (STAR*D trial) used both augmentation and substitution treatment modalities in separate treatment arms, each with a unique comparison group. These two arms were treated as separate studies in this review. Therefore, the evidence tables and narrative summarize six studies, with the caveat that two of the studies represented separate arms of the same trial. Full consensus was achieved between the two reviewers at each stage.

Figure 2 Randomized Controlled Trials Literature Flow

## SAMPLE CHARACTERISTICS

A total of 567 patients were evaluated across the studies. Patients were recruited from both mental health clinics (MHC) and primary care (PC) clinics. Three studies were conducted in the United States, two in Great Britain, and one in Canada. None of the studies recruited participants from VA clinics. Sample sizes ranged from 24 to 304 participants; two studies contributed 81% of the subjects.37, 40 Across all studies, participants’ average age was approximately 40-years-old, females compromised half to three quarters of the studies’ participants, and Caucasians represented at least 75% of the racial makeup in studies that reported ethnicity. The average length of patients’ current depressive episodes ranged from 30 to 123 weeks, with the average number of lifetime depressive episodes ranging from 2.2 to 8.5. For all studies, depression severity was moderate as determined by self-report measures. These characteristics are summarized in Table 1 and show significant heterogeneity in depression severity and chronicity. Sample characteristics for the psychotherapy and the comparison groups are provided if reported.

Table 1 Sample Characteristics

Study | Harley et al., 2008 | Kennedy et al., 2003 | Scott et al., 2000 | Thase et al., 2007 (Augmentation Arm) | Thase et al., 2007 (Substitution Arm) | Blackburn & Moore, 1997^*†^
Sample size, n
Psychotherapy | 13 | 23 | 80 | 65 | 36 | 17
Comparator | 11 | 21 | 78 | 117 | 86 | 20
Age, y (M±SD)
Psychotherapy | | 40.7±12.5 | 43.5 ± 9.8 | 40.6 ± 11.5 | 43.4 ± 14.7 | 37.8 ± 13.1
Comparator | 41.8 | 37.7±11.3 | 43.2 ±11.2 | 39.7 ± 13.5 | 41.5 ± 13.3 | 40.1 ± 12.7
Female, n
Psychotherapy | | 12 (52%) | 37 (46%) | 41 (63%) | 22 (61%) | 17 (77%)^*^
Comparator | 18 (75%) | 12 (57%) | 41 (53%) | 78 (67%) | 53 (62%) | 17 (65%)^*^
Caucasian, n | | _ | _ | | | _
Psychotherapy | | | | 52 (80%) | 28 (78%)
Comparator | 20 (83%) | | | 99 (85%) | 63 (73%)
Duration of current episode, wks (M±SD)
Psychotherapy | 28.7 ± 18.8 | 126 ± 170 | 62.9 | 129 ± 214 | 76 ± 135 | 30.4 ± 6.1
Comparator | 41.8 ± 53.6 | 120 ± 161 | 56.4 | 87 ± 206 | 115 ± 234 | 29.9 ± 5.6
Number of prior MDD episodes (M±SD)
Psychotherapy | Not | 2.1± 1.5 | 2 (median) | 7.3 ± 14.1 | 8.7 ± 18.8 | 4.1 ± 3.4
Comparator | Reported | 2.3 ± 1.4 | 2 (median) | 4.6 ± 5.4 | 8.4 ± 16.0 | 3.2 ± 2.2
Baseline HAM-D^a^ scores
Psychotherapy | 16.2 ± 4.5 | 12.1 ± 2.2 | 12.1 ± 2.7 | 17.8 ± 5.7 | 16.4 ± 6.2 | 11.8 ± 6.3
Comparator | 18.6 ± 4.7 | 11.6 ± 1.9 | 12.2 ± 2.9 | 16.0 ± 6.7 | 16.0 ± 6.7 | 10.6 ± 6.8
Baseline self-report scores | BDI^b^ | BDI | BDI | QIDS-SR^c^ | QIDS-SR | BDI
Psychotherapy | 27.3 ± 8.8 | 22.7 ± 8.6 | 21.7 ± 7.7 | 11.9 ± 4.3 | 11.2 ± 4.3 | 20.4 ± 11.1
Comparator | 27.4 ± 11.7 | 22.4 ± 10.3 | 22.3 ± 8.0 | 12.0 ± 4.6 | 12.1 ± 4.6 | 19.7 ± 14.2
Setting | MHC^d^ | MHC | MHC | MHC & PC^e^ | MHC & PC | MHC
Location | Boston, MA | Canada | England | U.S.A. | U.S.A. | Scotland

*† HAM-D, BDI and QIDS-SR scores based on smaller number that enrolled in phase 2 of the study following initial treatment with ADM

a HAM-D=Hamiltion Depresion Scale;

b BDI=Beck Depression Inventory;

bc QIDS-SR=Quick Inventory of Depressive Symptoms-Self Report;

d MHC=Mental Health Clinic;

e PC=Primary Care Clinic

To determine persistence, studies used different criteria but followed similar methodology. First, authors ensured that patients had a MDD at baseline. Second, patients underwent antidepressant (AD) treatment at adequate dose as first step treatment. Third, authors ensured that patients continued to have residual symptoms of MDD. All studies except Harley et al. (2008) reported criteria used to determine initial depression diagnosis. Two studies provided 1st step AD treatment whereas the others relied on non-study practitioners. HAM-D scores, either singly or in combination with BDI scores, were used predominantly to determine residual depression following AD treatment. The various criteria used to determine persistence are summarized in Table 2.

Table 2 Criteria to Determine Persistent Depression

Study | Harley et al., 2008 | Kennedy et al., 2003 | Scott et al., 2000 | Thase et al., 2007 | Blackburn & Moore, 1997
Criteria for initial depression diagnosis | Not Reported | HAM-D=17≥16 | MDD episode in previous 18 months according to DSM-III-R; residual symptoms for ≥8 weeks | Hx of MDD; HAM-D≥14 | Unipolar MDD using SADS^a^; HAM-D≥16
1^St^ step AD^b^ treatment: Type and Dosage | As prescribed by non-study psychiatrists | Moclobemide (300–600 mg/day) OR Paroxetine (20–40 mg/day) OR Sertraline (50–200 mg/day) OR Venlafaxine (75–225 mg/day) | Tricyclic antidepressant, SSRI, atypical AD, or MAOI; Minimum dose equivalent to 125 mg of amitriptyline) | Citalopram 20 mg/day titrated to 40 mg by week 4 if needed; Max. 60 mg/day by week 6 | As prescribed by non-study practitioners; Equivalent to 100 mg amitryptiline OR 45 mg phenelzine OR 20 mg of Sertraline
1^st^ Step AD Treatment: Duration | ≥ 6 weeks | 8–14 weeks | ≥ 8 weeks (at least 4 weeks of adequate dose) | 14 weeks | 16 weeks
Was 1^st^ AD step treatment provided in the study? | No | Yes | No | Yes | No
Criteria to Determine Persistence Following 1^st^ Step AD Treatment | MDD on SCID-I^c^ | HAM-D=8–15 | HAM-D≥8 & BDI≥9 | HAM-D≥14 | Moderate symptoms on BDI and HAM-D>11

a SADS=Schedule for Affective Disorders and Schizophrenia;

b AD=Antidepressant;

c SCID-I=Structured Clinical Interview for DSM-III-R, I

## STUDY DESIGN & INTERVENTIONS

Four studies used true randomization whereas the two studies from the STAR*D trial used an equipoise stratified randomization design, allowing patients to refuse to be randomized to treatments that would not be acceptable. Follow-up durations ranged from 8 to 104 weeks. Psychotherapy was examined as an augmentation treatment with antidepressant medication in four studies and as a substitution treatment replacing medication in two studies. In terms of the modality of psychotherapy provided, one small study used DBT41 whereas all others used CT.

All patients in the comparison groups were taking antidepressant medications, from a wide array of antidepressant classes. Three of the comparison groups received medication in a maintenance wait list condition, and three of the comparison groups received an active systematic alteration to their medication regimens (including both arms of the STAR*D trial). Retention rates in the different conditions ranged from 25% to 91%.

All studies used the Hamilton Depression Rating Scale (HAM-D) as their clinician administered diagnostic tool. Four studies used the Beck Depression Inventory (BDI) as their self-report measure whereas the two STAR*D trial studies used the QIDS-SR as their self-report measure. Mean baseline scores ranged from 11.2 to 17.3 on the HAM-D and from 20.0 to 27.3 on the BDI. Three trials were identified as good quality studies, two studies as fair, and one study as poor. Only three studies reported a sample size calculation. Study design and intervention overview is provided in Table 3.

Table 3 Study Design and Interventions

Study | Harley et al., 2008 | Kennedy et al., 2003 | Scott et al., 2000 | Thase et al., 2007 (Augment) | Thase et al., 2007 (Substitute) | Blackburn & Moore, 1997
Duration of follow up, wks | 16 | 8 | 20 | 14 | 14 | 104
Study design | RCT | RCT | RCT | Equipoise Stratified RCT | Equipoise Stratified RCT | RCT
Augmentation with Medication, or Substitution? | Augment | Augment | Augment | Augment | Substitute | Substitute
Psychotherapy Intervention Used | DBT^a^ Group | CT^b^ | CT | CT | CT | CT
# of sessions | 16 | 12 | 16 | 24 | 24 | 27
Comparator | ADM^c^ Continue | Lithium Augment | ADM Continue | ADM Augment | ADM Switch | ADM Continue
Power calculation | No | No | Yes | Yes | Yes | No
Quality rating | Fair | Fair | Good | Good | Good | Poor

a DBT=Dialectical Behavior Therapy;

b CT=Cognitive Therapy;

c ADM=Antidepressant Medication;

d NS=Not Significant

## STUDY RESULTS

Results from the six studies are summarized in Table 4 and are described in detail next. The four studies that describe psychotherapy as augmentation treatment are described first, followed by the two studies that used psychotherapy as a substitute for medications.

Table 4 Results of the Psychotherapy Intervention

Study | Harley et al., 2008 | Kennedy et al., 2003 | Scott et al., 2000 | Thase et al., 2007 (Augmentation) | Thase et al., 2007 (Substitution) | Blackburn & Moore, 1997
Retention rate, n
Psychotherapy | 10 (77%) | 17 (74%) | 61 (76%) | 59 (91%) | 30 (83%) | 6 (35%)
Comparator | 9 (82%) | 15 (71%) | 66 (85%) | 95 (81%) | 63 (73%) | 5 (25%)
Post-treatment HAM-D Scores (M±SD) | | | | Remission: | Remission:
Psychotherapy | 11.3 ± 5.3 | 14.8 ± 9.9 | 8.7±5.3 | 23.1% | 25.0% | 8.6±5.6
Comparator | 17.1 ± 6.2 | 9.2 ± 6.7 | 9.4 ± 5.3 | 33.3% | 27.9% | 9.3±7.2
Effect Size | d=1.45 | d=.32 | NS^a^ | NS | NS | NS
Post-treatment BDI Scores (M±SD)
Psychotherapy | 15.1 ±12.1 | 19.9 ± 10.3 | 13.8 ±9.6 | 8.2 ±5.1 | 9.1 ± 5.4 | 14.2 ± 9.9
Comparator | 25.9±16.3 | 15.1 ±11.4 | 16.1 ± 10.0 | 8.2 ± 4.8 | 9.1 ± 5.0 | 18.1 ± 13.1
Effect Size | d=1.31 | NS | NS | NS^*^ | NS^*^ | NS
Quality rating | Fair | Fair | Good | Good | Good | Poor

a NS=Not significant at p<.05;

* Results are for QIDS-C

### Psychotherapy as Augmentation to Antidepressant Medication

Harley et al. (2008) examined psychotherapy as an augmentation treatment to medication by randomizing 24 patients to either a DBT group (n=13) or to a wait list condition (WL; n=11).41 Patients in the DBT condition received 16 weekly sessions of a 90-minute coping skills group in addition to remaining on antidepressant medication, while patients in the WL condition continued taking antidepressant medication and meeting with their psychiatrists and healthcare providers as usual. Treatment resistance in this study was defined as current depression determined by a structured evaluation after stable, adequate treatment with antidepressant medication for at least six weeks. Post treatment analyses found significant differences between the two groups for mean scores on the HAM-D (DBT=11.3; WL=17.1; F = 4.63, p < .05) and BDI (DBT=15.1; WL=25.9; F = 9.50, p < .01), such that patients in the DBT group evidenced more clinical improvement than those in the WL condition. The retention rate was 77% in the DBT group and 82% in the WL condition. Given the small sample size and confound of allowing patients to continue in non-CBT individual therapy, we assigned an overall quality rating of “fair” to this study.

Kennedy et al. (2003) examined psychotherapy as an augmentation treatment to medication by randomizing 44 patients to either cognitive therapy (CT; n=23) or lithium augmentation (LA; n=21).42 Patients in the CT condition received 12 psychotherapy sessions delivered over eight weeks and were seen every four weeks for a medication checkup, while patients in the LA condition had their antidepressant medication augmented with lithium carbonate (starting dose of 600mg/day) and were seen every two weeks for clinical management. Treatment resistance in this study was defined as having a HAM-D score between 8 and 15 after 8–14 weeks of treatment with antidepressant medication. Post treatment analyses found a significant difference between the two groups for mean scores on the HAM-D (CT=14.8; LA=9.2; t = 2.02, p = .04), such that patients in the LA condition showed a greater decrease in depressive symptoms than those in the CT condition. No significant post treatment difference was found between the two groups for mean scores on the BDI (CT=19.9; LA=15.1). The retention rate was 74% in the CT condition and 71% in the LA condition. One limitation of this study is that it only included “partial responders” to initial antidepressant medication treatment (i.e., HAM-D score from 8 to 15) and excluded “non-responders” (i.e., HAM-D ≥ 16). It also did not report a sample size calculation and probably lacked sufficient statistical power to detect clinically important differences. We assigned an overall quality rating of “fair” to this study.

Multiple articles were identified for a study that examined psychotherapy as an augmentation treatment to medication.40, 43–46 Data were primarily extracted from Scott et al. (2000).40 In this good quality study, 158 patients were randomized to either CT (n=80) or clinical management (CM; n=78). An analysis of the pre-set sample size of 160 gave 80% power to detect a reduction in relapse rates from 40% in one group to 20% in the other at p = .05. Patients in the CT condition received 16 psychotherapy sessions over 20 weeks in addition to continuing on antidepressant medication, while patients in the CM condition continued on antidepressant treatment and were seen every four weeks for 30-minite medication management appointments. Treatment resistance in this study was defined as having a HAM-D score ≥ 8 and BDI score ≥ 9 after at least eight weeks of adequate treatment with an antidepressant medication. Participants had an average age of 43 and 49% were female. The average duration of participants’ current depressive episode was 60 weeks (CT=63; CM=56), with both groups having a median of two lifetime episodes of depression. While participants in both conditions improved, post treatment analyses found no significant differences between the two groups for mean scores on the HAM-D (CT=8.7; CM=9.4) or BDI (CT=13.8; CM=16.1). Retention was measured as staying in until relapse or until the end of the study at 68 weeks, resulting in a 76% retention rate in the CT condition and an 85% retention rate in the CM condition. A limitation of this study is that it allowed for patients with partially remitted depressive symptoms and no diagnosis of current major depression to participate.

The STAR*D trial32, 37, 47, 48 was a multistage, multicenter trial that examined both psychotherapy and medication as either augmentation or substitution treatments to initial treatment with citalopram. Treatment resistance in the STAR*D trial was defined as having a HAM-D score ≥ 14 after 14 weeks of treatment with citalopram. The equipoise-stratified randomization design employed in this study allowed patients to refuse randomization to treatment strategies that they found unacceptable, which resulted in asymmetrical sample sizes for different treatment arms. Less than one third of participants agreed to true randomization, which is a significant limitation of the study in terms of internal validity. Analyses conducted prior to data collection indicate that too few patients were randomized to the different treatment conditions to achieve the originally desired power. However, this study represents the best external validity given that they accounted for patient preferences, which is similar to what may be expected in primary care settings. We assigned an overall quality rating of “good” to both the augmentation and substitution arms of this study. Data are presented separately below, first examining psychotherapy and medication as an augmentation to citalopram and then examining psychotherapy and medication as substitution treatments to replace citalopram. Data were primarily extracted from Thase et al. (2007).37

In the augmentation arm, 182 patients were assigned to either augmentation cognitive therapy (A-CT; n=65) or augmentation antidepressant medication (A-ADM; n=117). Patients in the A-CT condition received 16 psychotherapy sessions over 12 weeks in addition to continuing on citalopram, while patients in the A-ADM condition had their treatment with citalopram augmented with either bupropion or buspirone. Participants had an average age of 40, 65% were female, and 83% were Caucasian. The average duration of participants’ current depressive episode was 102 weeks (A-CT=129; A-ADM=87), with a mean of 5.6 lifetime episodes of depression (A-CT=7.3; A-ADM=4.6). There were no significant between-group differences in mean baseline depression scores on the HAM-D (A-CT=17.8; A-ADM=16.0) or QIDS-C (A-CT=11.9; A-ADM=12.0). While participants in both conditions evidenced significant improvement, post treatment analyses found no significant differences between the two groups for percent remitted on the HAM-D (A-CT=23.1%; A-ADM=33.3%) or for mean scores on the QIDS-C (A-CT=8.2; A-ADM=8.2). However, participants in the A-ADM condition did demonstrate quicker benefit than participants in the A-CT condition. The retention rate was 91% in the A-CT condition (although only 27% of patients completed at least 16 sessions) and 81% in the A-ADM condition.

In summary, the two good quality, moderate sized trials showed equal benefit from augmenting antidepressant medication with 16 to 24 sessions of cognitive therapy and from active management of depression with medication, whereas a small fair quality study showed greater benefit from lithium augmentation than cognitive therapy augmentation. A single fair quality trial showed short-term benefit from 16 sessions of DBT. Because study populations and designs were conceptually heterogeneous, a summary estimate of effect was not calculated.

### Psychotherapy as Step-2 Substitution for Antidepressant Medication

In the substitution arm of STAR*D, 122 patients were randomized using an equipoise-stratified randomization design to either substitution cognitive therapy (S-CT; n=36) or substitution antidepressant medication (S-ADM; n=86). Patients in the S-CT condition discontinued treatment with citalopram and received 16 psychotherapy sessions over 12 weeks, while patients in the S-ADM condition discontinued citalopram and switched to treatment with bupropion, sertraline, or venlafaxine. Participants had an average age of 42, 61% were female, and 75% were Caucasian. The average duration of participants’ current depressive episode was 103 weeks (S-CT=76; S-ADM=115), with a mean of 8.5 lifetime episodes of depression (S-CT=8.7; S-ADM=8.4). There were no significant between-group differences in mean baseline depression scores on the HAM-D (S-CT=16.4; S-ADM=16.0) or QID-S (S-CT=11.2; S-ADM=12.1). While participants in both conditions evidenced significant improvement, post treatment analyses found no significant differences between the two groups for percent remitted on the HAM-D (S-CT=25.0%; S-ADM=27.9%) or for mean scores on the QID-S (S-CT=9.1; S-ADM=9.1). The retention rate was 83% in the S-CT condition (although only 35% completed at least 16 sessions) and 73% in the S-ADM condition.

The poor quality study by Blackburn and Moore (1997) examined psychotherapy as a substitution treatment to replace antidepressant medication by randomizing 37 patients to either CT (n=17) or antidepressant medication (ADM; n=20).49 Patients in the CT condition received 27 psychotherapy sessions over 104 weeks, while patients in the ADM condition continued on an antidepressant medication of their prescriber’s choice (prescribers were also free to switch medications) and were seen by their providers about every three weeks. Treatment resistance was not specifically defined in this study, but after 16 weeks of treatment with an antidepressant medication, patients continued to have depressive symptoms at a level comparable to that of the other patient populations included in this review (see Table 1). Post treatment analyses found no significant differences between the two groups for mean scores on the HAM-D (CT=8.6; ADM=9.3) or BDI (CT=14.2; ADM=18.1). The retention rate was 35% in the CT condition and was 25% in the ADM condition. The “poor” quality rating was based on the poor retention rate, lack of statistical power, unorthodox length of CT treatment protocol, and lack of operational definition for treatment resistance.

In summary, a moderate-sized, good quality study and a small, poor quality study found equal benefit from substituting cognitive therapy for antidepressant treatment and from continuing management of depression with medication in patients with treatment resistant MDD.