# REFERENCES

1 Papakostas G, Fava M. Predictors, moderators, and mediators (correlates) of treatment outcome in major depressive disorder. Dialogues in Clinical Neuroscience. 2008;10(4):439-451. [pmid: 19170401].
2 Hasin DS, Goodwin RD, Stinson FS, Grant BF. Epidemiology of major depressive disorder: results from the National Epidemiologic Survey on Alcoholism and Related Conditions. Arch Gen Psychiatry. 2005;62(10):1097-106. [pmid: 16203955].
3 Kessler RC, Berglund P, Demler O, Jin R, Merikangas KR, Walters EE. Lifetime prevalence and age-of-onset distributions of DSM-IV disorders in the National Comorbidity Survey Replication. Arch Gen Psychiatry. 2005;62(6):593-602. [pmid: 15939837].
4 Hankin CS, Spiro A 3rd, Miller DR, Kazis L. Mental disorders and mental health treatment among U.S. Department of Veterans Affairs outpatients: the Veterans Health Study. Am J Psychiatry. 1999;156(12):1924-30. [pmid: 10588406].
5 Katon WJ. Clinical and health services relationships between major depression, depressive symptoms, and general medical illness. Biol Psychiatry. 2003;54(3):216-26. [pmid: 12893098].
6 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). Jama. 2003;289(23):3095-105. [pmid: 12813115].
7 Kronish IM, Rieckmann N, Halm EA, et al. Persistent depression affects adherence to secondary prevention behaviors after acute coronary syndromes. J Gen Intern Med. 2006;21(11):1178-83. [pmid: 16899061].
8 Seelig MD, Katon W. Gaps in depression care: why primary care physicians should hone their depression screening, diagnosis, and management skills. J Occup Environ Med. 2008;50(4):451-8. [pmid: 18404018].
9 Olfson M, Marcus SC, Druss B, Elinson L, Tanielian T, Pincus HA. National trends in the outpatient treatment of depression. JAMA. 2002;287(2):203-9. [pmid: 11779262].
10 Karasu TB, Gelenberg A, Merriam A, Wang P. Practice guideline for the treatment of patients with major depressive disorder. 2nd ed. Arlington, VA. American Psychiatric Association. 2000. APA Practice Guidelines.
11 Fochtmann LJ, Gelenberg AJ. Guideline watch: Practice guideline for the treatment of patients with depressive disorder. 2nd ed. Arlington, VA. American Psychiatric Association. 2005. APA Practice Guidelines.
12 Barbui C, Furukawa TA, Cipriani A. Effectiveness of paroxetine in the treatment of acute major depression in adults: a systematic re-examination of published and unpublished data from randomized trials. Cmaj. 2008;178(3):296-305. [pmid: 18227449].
13 Cipriani A, Furukawa TA, Geddes JR, et al. Does randomized evidence support sertraline as first-line antidepressant for adults with acute major depression?A systematic review and meta-analysis. J Clin Psychiatry. 2008;69(11):1732-42. [pmid: 19026250].
14 Kennedy SH, Andersen HF, Thase ME. Escitalopram in the treatment of major depressive disorder: a meta-analysis. Curr Med Res Opin. 2009;25(1):161-75. [pmid: 19210149].
15 Mulrow CD, Williams JW Jr, Chiquette E, et al. Efficacy of newer medications for treating depression in primary care patients. Am J Med. 2000;108(1):54-64. [pmid: 11059441].
16 Watanabe N, Omori IM, Nakagawa A, et al. Mirtazapine versus other antidepressants in the acute-phase treatment of adults with major depression: systematic review and meta-analysis. J Clin Psychiatry. 2008;69(9):1404-15. [pmid: 19193341].
17 Simon GE, Ludman E, Unutzer J, Bauer MS. Design and implementation of a randomized trial evaluating systematic care for bipolar disorder. Bipolar Disord. 2002;4(4):226-36. [pmid: 12190711].
18 Wampold BE. The Great Psychotherapy Debate: Models, Methods, and Findings. Mahwah, NJ. Lawrence Erlbaum Associates. 2001.
19 Bortolotti B, Menchetti M, Bellini F, Montaguti MB, Berardi D. Psychological interventions for major depression in primary care: a meta-analytic review of randomized controlled trials. Gen Hosp Psychiatry. 2008;30(4):293-302. [pmid: 18585531].
20 Butler AC, Chapman JE, Forman EM, Beck AT. The empirical status of cognitive-behavioral therapy: a review of meta-analyses. Clin Psychol Rev. 2006;26(1):17-31. [pmid: 16199119].
21 Craighead WE, Sheets ES, Brosse AL, Ilardi SS. Psychosocial treatments for major depressive disorder. Nathan PE, Gorman JM, editors. A guide to treatments that work. 3rd ed. New York. Oxford. 2007:289-293.
22 DeRubeis RJ, Gelfand LA, Tang TZ, Simons AD. Medications versus cognitive behavior therapy for severely depressed outpatients: mega-analysis of four randomized comparisons. Am J Psychiatry. 1999;156(7):1007-13. [pmid: 10401443].
23 DeRubeis RJ, Hollon SD, Amsterdam JD, et al. Cognitive therapy vs medications in the treatment of moderate to severe depression. Archives of General Psychiatry. 2005;62(4):409-16. [pmid: 15809408].
24 Pampallona S, Bollini P, Tibaldi G, Kupelnick B, Munizza C. Combined pharmacotherapy and psychological treatment for depression: a systematic review. Archives of General Psychiatry. 2004;61(7):714-9. [pmid: 15237083].
25 de Maat SM, Dekker J, Schoevers RA, de Jonghe F. Relative efficacy of psychotherapy and combined therapy in the treatment of depression: a meta-analysis. Eur Psychiatry. 2007;22(1):1-8. [pmid: 17194571].
26 Fava M, Rush AJ. Current status of augmentation and combination treatments for major depressive disorder: a literature review and a proposal for a novel approach to improve practice. Psychother Psychosom. 2006;75(3):139-53. [pmid: 16636629].
27 Segal Z, Vincent P, Levitt A. Efficacy of combined, sequential and crossover psychotherapy and pharmacotherapy in improving outcomes in depression. J Psychiatry Neurosci. 2002;27(4):281-90. [pmid: 12174737].
28 Cornwall PL, Scott J. Partial remission in depressive disorders. Acta Psychiatr Scand. 1997;95(4):265-71. [pmid: 9150818].
29 Fava M. Diagnosis and definition of treatment-resistant depression. Biol Psychiatry. 2003;53(8):649-59. [pmid: 12706951].
30 Stimpson N, Agrawal N, Lewis G. Randomised controlled trials investigating pharmacological and psychological interventions for treatment-refractory depression. Systematic review. Br J Psychiatry. 2002;181:284-94. [pmid: 12356654].
31 Trivedi MH. Major depressive disorder: remission of associated symptoms. J Clin Psychiatry. 2006;67(Suppl 6):27-32. [pmid: 16848674].
32 Rush AJ, Fava M, Wisniewski SR, et al. Sequenced treatment alternatives to relieve depression (STAR*D): rationale and design. Controlled Clinical Trials. 2004;25(1):119-42. [pmid: 15061154].
33 Rush AJ, Wisniewski SR, Warden D, et al. Selecting among second-step antidepressant medication monotherapies: predictive value of clinical, demographic, or first-step treatment features. Archives of General Psychiatry. 2008;65(8):870-80. [pmid: 18678792].
34 Corey-Lisle PK, Nash R, Stang P, Swindle R. Response, Partial Response, and Non-response in Primary Care Treatment of Depression. Archives of Internal Medicine. 2004;164(11):1197-1204. [pmid: 15197045].
35 Sherbourne C, Schoenbaum M, Wells KB, Croghan TW. Characteristics, treatment patterns, and outcomes of persistent depression despite treatment in primary care. General Hospital Psychiatry. 2004;26(2):106-14. [pmid: 15038927].
36 Souery D, Oswald P, Massat I, et al. Clinical factors associated with treatment resistance in major depressive disorder: results from a European multicenter study. Journal of Clinical Psychiatry. 2007;68(7):1062-70. [pmid: 17685743].
37 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. American Journal of Psychiatry. 2007;164(5):739-52. [pmid: 17475733].
38 Markowitz JC. When should psychotherapy be the treatment of choice for major depressive disorder?. Current Psychiatry Reports. 2008;10(6):452-7. [pmid: 18980727].
39 Mitchell AJ. Depressed patients and treatment adherence. Lancet. 2006;367(9528):2041-3. [pmid: 16798371].
40 Scott J, Teasdale JD, Paykel ES, et al. Effects of cognitive therapy on psychological symptoms and social functioning in residual depression. British Journal of Psychiatry. 2000;177:440-6. [pmid: 11059998].
41 Harley R, Sprich S, Safren S, Jacobo M, Fava M. Adaptation of dialectical behavior therapy skills training group for treatment-resistant depression. Journal of Nervous and Mental Disease. 2008;196(2):136-43. [pmid: 18277222].
42 Kennedy SH, Segal ZV, Cohen NL, Levitan RD, Gemar M, Bagby RM. Lithium carbonate versus cognitive therapy as sequential combination treatment strategies in partial responders to antidepressant medication: an exploratory trial. Journal of Clinical Psychiatry. 2003;64(4):439-44. [pmid: 12716247].
43 Paykel ES, Scott J, Cornwall PL, et al. Duration of relapse prevention after cognitive therapy in residual depression: follow-up of controlled trial. Psychological Medicine. 2005;35(1):59-68. [pmid: 15842029].
44 Paykel ES, Scott J, Teasdale JD, et al. Prevention of relapse in residual depression by cognitive therapy: a controlled trial. Archives of General Psychiatry. 1999;56(9):829-35. [pmid: 12884889].
45 Scott J, Palmer S, Paykel E, Teasdale J, Hayhurst H. Use of cognitive therapy for relapse prevention in chronic depression. Cost-effectiveness study. British Journal of Psychiatry. 2003;182:221-7. [pmid: 12611785].
46 Teasdale JD, Scott J, Moore RG, Hayhurst H, Pope M, Paykel ES. How does cognitive therapy prevent relapse in residual depression? Evidence from a controlled trial. Journal of Consulting and Clinical Psychology. 2001;69(3):347-57. [pmid: 11495165].
47 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: a STAR*D report. American Journal of Psychiatry. 2006;163(11):1905-17. [pmid: 17074942].
48 Wisniewski SR, Fava M, Trivedi MH, et al. Acceptability of second-step treatments to depressed outpatients: a STAR*D report. American Journal of Psychiatry. 2007;164(5):753-60. [pmid: 17475734].
49 Blackburn IM, Moore RG. Controlled acute and follow-up trial of cognitive therapy and pharmacotherapy in out-patients with recurrent depression. British Journal of Psychiatry. 1997;171:328-34. [pmid: 9373420].
50 Wolf NJ, Hopko DR. Psychosocial and pharmacological interventions for depressed adults in primary care: a critical review. Clinical Psychology Review. 2008;28(1):131-61. [pmid: 17555857].
51 Bower P, Gilbody S, Richards D, Fletcher J, Sutton A. Collaborative care for depression in primary care. Making sense of a complex intervention: systematic review and meta-regression. Br J Psychiatry. 2006;189:484-93. [pmid: 17139031].
52 Lave JR, Frank RG, Schulberg HC, Kamlet MS. Cost-effectiveness of treatments for major depression in primary care practice. Archives of General Psychiatry. 1998;55(7):645-51. [pmid: 9672056].
53 Barrett B, Byford S, Knapp M. Evidence of cost-effective treatments for depression: a systematic review. J Affect Disord. 2005;84(1):1-13. [pmid: 15620380].
54 Leff J, Vearnals S, Brewin CR, et al. The London Depression Intervention Trial. Randomised controlled trial of antidepressants v. couple therapy in the treatment and maintenance of people with depression living with a partner: clinical outcome and costs. British Journal of Psychiatry. 2000;177:95-100. [pmid: 11026946].
55 Simpson S, Corney R, Fitzgerald P, Beecham J. A randomized controlled trial to evaluate the effectiveness and cost-effectiveness of psychodynamic counselling for general practice patients with chronic depression. Psychological Medicine. 2003;33(2):229-39. [pmid: 12622302].
56 Mynors-Wallis L, Davies I, Gray A, Barbour F, Gath D. A randomised controlled trial and cost analysis of problem-solving treatment for emotional disorders given by community nurses in primary care. Br J Psychiatry. 1997;170:113-9. [pmid: 9093498].
57 Guthrie E, Moorey J, Margison F, et al. Cost-effectiveness of brief psychodynamic-interpersonal therapy in high utilizers of psychiatric services. Arch Gen Psychiatry. 1999;56(6):519-26. [pmid: 10359466].
58 Russell JM, Hawkins K, Ozminkowski RJ, et al. The cost consequences of treatment-resistant depression. J Clin Psychiatry. 2004;65(3):341-7. [pmid: 15096073].
59 Unutzer J, Katon W, Callahan CM, et al. Collaborative care management of late-life depression in the primary care setting: a randomized controlled trial. JAMA. 2002;288(22):2836-45. [pmid: 12472325].
60 Williams JW Jr, Gerrity M, Holsinger T, Dobscha S, Gaynes B, Dietrich A. Systematic review of multifaceted interventions to improve depression care. Gen Hosp Psychiatry. 2007;29(2):91-116. [pmid: 17336659].
61 Katon W, Von Korff M, Lin E, et al. Stepped collaborative care for primary care patients with persistent symptoms of depression: a randomized trial. Arch Gen Psychiatry. 1999;56(12):1109-15. [pmid: 10591288].
62 Williams JM, Teasdale JD, Segal ZV, Soulsby J. Mindfulness-based cognitive therapy reduces overgeneral autobiographical memory in formerly depressed patients. Journal of Abnormal Psychology. 2000;109(1):150-5. [pmid: 10740947].
63 Bruce ML, Ten Have TR, Reynolds CF 3rd, et al. Reducing suicidal ideation and depressive symptoms in depressed older primary care patients: a randomized controlled trial. JAMA. 2004;291(9):1081-91. [pmid: 14996777].